# Background

The Effective Health Care Program (EHC) researches available health care tests and treatments to determine whether there are significant advantages or disadvantages with different approaches. The results of this comparative effectiveness research can help people make better decisions about what health care they want to have, and can help clinicians and health care purchasers to focus on the best tests and treatments. Initial work in this program originates from Section 1013 of the Medicare Prescription Drug, Improvement, and Modernization Act (MMA) of 2003. Section 1013 authorizes AHRQ to conduct and support research with a focus on outcomes, comparative clinical effectiveness, and appropriateness of pharmaceuticals, devices, and health care services. The Effective Health Care Program follows three approaches to research in order to provide current, unbiased evidence on health care interventions.

- Review and synthesize published and unpublished scientific evidence.
- Promote and generate new scientific evidence and analytic tools.
- Compile the findings and translate them into a variety of useful formats for stakeholders.

Systematic reviews by the Evidence-based Practice Centers (EPC) Program contribute to the first area of the EHC Program. EPC research reviews provide comprehensive appraisal and synthesis of evidence following explicit methodological criteria.

A Comparative Effectiveness Review (CER) is a unique type of systematic review, which synthesizes the available scientific evidence on a specific topic. CERs expand the scope of a typical systematic review, which focuses on the effectiveness of a single intervention, by comparing the relative benefits and harms among a range of available treatments or interventions for a given condition. In doing so, CERs more closely parallel the decisions facing clinicians, patients and policymakers, who must choose among a variety of alternatives in making diagnostic, treatment, and health care delivery decisions.

In choosing topics for CERs, a number of criteria are considered including the burden of illness; evidence suggesting underuse or overuse; the cost of the intervention or of not treating the illness; controversy surrounding the treatment; and interventions intended to treat conditions that disproportionately affected women, traditionally underserved minorities, and the elderly (this group was subsequently expanded to include children). The first 14 CERs were conducted from 2005 through 2007. The topics and completion dates are shown in Table 1.

Table 1 Topics of Initial CERs

Report Number and Title | Publication
1. Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease | 12/2005
2. Effectiveness of Noninvasive Diagnostic Tests for Breast Abnormalities | 02/2006
3. Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment | 05/2006
4. Comparative Effectiveness and Safety of Analgesics for Osteoarthritis | 09/2006
5. Comparative Management Strategies for Renal Artery Stenosis^*^ | 10/2006
6. Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotic | 01/2007
7. Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression | 01/2007
8. Comparative Effectiveness and Safety of Oral Diabetes Medications for Adults With Type 2 Diabetes^*^ | 07/2007
9. Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease | 10/2007
10. Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension | 11/2007
11. Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults | 11/2007
12. Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis | 12/2007
13. Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer | 02/2008
14. Comparative Effectiveness, Safety, and Indications of Insulin Analogues in Premixed Formulations for Adults with Type 2 Diabetes^#^ | 09/15/08

* AHRQ decided to update this report; thus, it was not considered in this report.

# This report was completed too recently for consideration.

AHRQ recognizes that periodic assessments of the evidence base supporting each of the comparative effectiveness reviews is an important and necessary part of the Effective Health Care (EHC) Program. The rapidity with which new research findings accumulate makes it imperative that the evidence be assessed periodically to determine the need for a full-scale update. The EHC Program, then, initiated concurrent and parallel work to address this need both methodologically and programmatically. The development of methods guidance for updating was initiated to inform the research of systematic reviewers. This methodologic guidance will supplement the EHC Methods Guide for Comparative Effectiveness Reviews (www.effectiveheathcare.gov). In parallel with the methods effort, an initial, rapid program assessment was commissioned to assess the need for the findings of the CERs completed to that point to be updated. The Southern California Evidence-based Practice Center (SCEPC) was tasked with conducting this assessment. Findings from the assessment were presented to AHRQ for consideration within the usual program criteria to prioritize the topics for updating within the EHC Program. This document presents the findings from the assessment for public information and transparency.

The assessment of the evidence base included the following questions and other consideration depending on the topic of the comparative effectiveness review.

- Have new medications, procedures, or devices been introduced?
- Have the existing medications, procedures, or devices been approved for new indications?
- Have any new advisories or alerts been issued?
- Has there been a change in scope (e.g., new patient populations, new outcomes)?
- Is there new evidence from new studies or studies that were incomplete at the time of the existing report?
- Have new methodologies been introduced (e.g., new statistical techniques or significant changes in the Comparative Effectiveness Review Methodology Guide)?