# Assessment of Need to Update CERs

To assess the need for the first set of effectiveness reviews to be updated, the SCEPC employed a modification of a method devised by Shekelle and colleagues (Shekelle et al, 2001) to conduct an abbreviated review of the literature. The process relied on a combination of expert opinion, and limited search and review of the peer reviewed literature and the Federal Food and Drug Administration (FDA) website (MedWatch Database) to assess whether a CER needs to be updated. The methodology was applied to each CER separately and independently.

## Expert Consultation

Based on our earlier work (Shekelle et al, 2001), we drafted a brief letter that posed two questions about each conclusion reached in the original reports. The letter incorporated an introduction to the study, the original key questions, the conclusions corresponding to those questions, and our questions regarding updating, and it asked the experts to offer their opinion as to whether the conclusion was still valid or was possibly, probably, or definitely in need of updating (Figure 1).

Figure 1 Sample Letter Excerpt (for Key Question 1 from CER#1)

We conducted pilot tests of the initial letter among the principal investigator and several Technical Expert Panel (TEP) members for CER #12 (Therapies for Low Bone Density) as well as with the subject matter expert for CER #6 (Offlabel Uses of Atypical Antipsychotics), both of which were conducted by the SCEPC.

Based on the method used in our earlier report as well as the method of Gartlehner and colleagues (2004), we sought to include opinions from a minimum of 4 experts on each report topic, including that of the director of the EPC that conducted the original report (or the project leader, if it was not the EPC director). We contacted each of the EPC directors by express mail, asking them to provide their assessments of the need to update their reports (that is, the relevance of the conclusions) using the letter described above. We also asked for the names of at least three TEP members whom they believed were in a position to comment on the need for an update. We then contacted each of these experts to ask their participation. For reports for which no TEP had been appointed, we asked for the names of, and contacted, peer reviewers of the original report or other subject matter experts in the respective fields. If the PI failed to respond or could not recommend experts, we consulted relevant experts who had worked with the SCEPC on other projects. Experts who responded were sent the letter that incorporated key questions and conclusions for the report in question. Each respondent was offered an honorarium of $100. The experts’ responses were entered into an Excel spreadsheet. These responses were later summarized along with the findings of the literature searches (see below).

## Literature Searches

We followed the method employed by Shekelle and colleagues for their assessment of the need to update the AHRQ Clinical Practice Guidelines. This method employed an abbreviated literature search strategy that focused on five major general-interest medical journals (Annals of Internal Medicine, British Medical Journal, Journal of the American Medical Association, The Lancet, and New England Journal of Medicine) supplemented with a small number of specialty journals tailored to each topic, as recommended by content experts (Shekelle et al, 2001) or, in a small number of cases, those most frequently cited in the original CER. The starting dates for searches were purposely set at one to two years prior to the ending dates of the original searches to capture any studies not included in the original searches.

With the exception of the literature searches conducted for reports #6 and 7, the title lists that resulted from all remaining literature searches were screened by a single member of the SCEPC staff or a subject matter expert (with prior EPC experience); the title lists for reports #6 and 7 were dually screened to ensure general agreement among reviewers. Abstracts were obtained for titles that appeared relevant, and the abstracts were further screened for inclusion. Inclusion/exclusion criteria were flexible: The only factors considered were whether the study being reported was relevant to one of the key questions/conclusions and whether the design consisted of a controlled trial or large observational study (systematic reviews were also included).

Added to the results of the searches were any articles cited or recommended by the experts and not already identified in our searches.

For each included report, study conditions, outcomes, and findings were abstracted to an evidence table. When necessary, full text articles were obtained to abstract information not found in abstracts.

## FDA MedWatch and Canadian Health Services Database Searches

To supplement our searches of the peer-reviewed literature, the Scientific Resource Center (SRC) at Oregon Health Sciences University (OHSU) searched the FDA MedWatch database and the Canadian Health Services (CHS) pharmaceutical database for any reports about drugs considered in the original CERs that were issued since (or 1 to 2 years prior to) the searches conducted for the original CERs.

## Compilation of Findings

For each CER, we constructed a summary table that included the key questions, the original conclusions, and the findings of the new literature search, the expert assessments, and any FDA or CHS reports that pertained to each key question. To assess the conclusions in terms of the evidence that they might need updating, we used a 4-category scheme:

- Original conclusion is still valid and this portion of the CER does not need updating
- Original conclusion is possibly out of date and this portion of the CER may need updating
- Original conclusion is probably out of date and this portion of the CER may need updating
- Original conclusion is out of date

In making the decision to classify a CER conclusion into one category or another, we used the following factors when making our assessments:

- If we found no new evidence or only confirmatory evidence and all responding experts assessed the CER conclusion as still valid, we classified the CER conclusion as still valid.
- If we found some new evidence that might change the CER conclusion, and/or a minority of responding experts assessed the CER conclusion as having new evidence that might change the conclusion, then we classified the CER conclusion as possibly out of date.
- If we found substantial new evidence that might change the CER conclusion, and/or a majority of responding experts assessed the CER conclusion as having new evidence that might change the conclusion, then we classified the CER conclusion as probably out of date.

If we found new evidence that rendered the CER conclusion out of date or no longer applicable, we classified the CER conclusion as out of date. Recognizing that our literature searches were limited, we reserved this category only for situations where a limited search would produce prima facie evidence that a conclusion was out of date, such as the withdrawal of a drug or surgical device from the market, a black box warning from FDA, etc.

We then also assessed each CER as a whole regarding the need for updating. Each CER consists of multiple conclusions. In all cases we assessed, there was none in which all conclusions were assessed “still valid” or “possibly/probably out of date.” Hence, a conclusion was made regarding which CERs are most in need of updating now. Recognizing that resources are likely limited, we did not judge the presence of any individual conclusion that was “possibly out of date” as a necessary reason to update the entire CER. Rather we made our decisions based on the following considerations:

- How much of the CER is possibly, probably, or certainly out of date?
- How out of date is that portion of the CER? For example, would the potential changes to the conclusions involve refinement of original estimates or do the potential changes mean some therapies are no longer favored or may not exist? Is the portion of the CER that is probably or certainly out of date an issue of safety (a drug withdrawn from the market, a black box warning) or the availability of a new drug within class (the latter being less of a signal to update than the former)?