# Search Strategies by topic

## CER 1 – GERD – 2008 UPDATE: SEARCH METHODOLOGY

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2005–2008

SEARCH STRATEGY:

gastroesophageal reflux OR gastro-esophageal reflux OR gastro-oesophageal reflux OR gastrooesophageal reflux OR esophagitis OR oesophagitis OR gerd OR gord OR bile reflux OR heartburn OR acid reflux OR dyspep*

AND

Search "JAMA"[Journal:__jrid5346] OR "N Engl J Med"[Journal:__jrid5985] OR "Lancet"[Journal:__jrid5470] OR "Br Med J"[Journal:__jrid1912] OR "Br Med J (Clin Res Ed)"[Journal:__jrid1913] OR "BMJ"[Journal:__jrid2274] OR "Ann Intern Med"[Journal:__jrid596] OR "Gastroenterology"[Journal:__jrid3841] OR "Am J Gastroenterol"[Journal:__jrid426] OR "Clin Gastroenterol Hepatol"[Journal:__jrid31839] OR "Gut"[Journal:__jrid3923] OR "Aliment Pharmacol Ther"[Journal:__jrid1160]

AND

randomized controlled trials[mh] OR randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt]

TOTAL NUMBER OF ITEMS RETRIEVED: 302

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane DARE – No date limit allowed

SEARCH STRATEGY:

gastroesophageal reflux OR gastro-esophageal reflux OR gastro-oesophageal reflux OR gastrooesophageal reflux OR esophagitis OR oesophagitis OR gerd OR gord OR bile reflux OR heartburn OR acid reflux OR dyspepsia OR dyspeptic OR dyspepsic {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 7

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Database of Systematic Reviews – All years

SEARCH STRATEGY:

gastroesophageal reflux OR gastro-esophageal reflux OR gastro-oesophageal reflux OR gastrooesophageal reflux OR esophagitis OR oesophagitis OR gerd OR gord OR bile reflux OR heartburn OR acid reflux OR dyspepsia OR dyspeptic OR dyspepsic {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 6

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Central (Controlled Trials Register) – 2005–2008

SEARCH STRATEGY:

gastroesophageal reflux OR gastro-esophageal reflux OR gastro-oesophageal reflux OR gastrooesophageal reflux OR esophagitis OR oesophagitis OR gerd OR gord OR bile reflux OR heartburn OR acid reflux OR dyspepsia OR dyspeptic OR dyspepsic {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 21

## CER 2 – BREAST NEOPLASMS – 2008 UPDATE: SEARCH METHODOLOGY

SEARCH #1A:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2005–2008

LIMITERS:

English

Human

SEARCH STRATEGY:

breast neoplasms[mh] OR breast diseases[mh] OR breast cancer* OR breast neoplasm*[tiab] OR breast carcinoma* OR breast disease*

AND

diagnosis OR diagnose OR diagnostic OR di[sh] OR “gold standard” OR “ROC” OR “receiver operating characteristic” OR sensitivity and specificity[mh] OR likelihood OR “false positive” OR “false negative” OR “true positive” OR “true negative” OR “predictive value" OR accuracy OR gold standard OR ROC OR receiver operating characteristic OR false positive OR false negative OR true positive OR true negative OR predictive value

AND

(ultrasonography[sh] OR ultrasonography, mammary[mh] OR echogra* OR echomammogr* OR sonogr* OR sonomammogr* OR ultrasound OR ultrason*) OR noninvasive OR non-invasive OR magnetic resonance imaging[mh] OR “magnet strength” OR miraluma OR pulse sequence OR MR OR MRI OR magnet strength OR nuclear magnetic resonance OR NMR OR (FDG* OR fluorodeoxyglucose F 18[mh] OR PET[ti] OR organotechnetium compounds/du[mh] OR positron emission tomography OR sestamibi OR technetium Tc 99m Sestamibi/du[mh] OR tomography, emission-computed[mh] OR tetrofosmin OR gamma camera OR gammagraph* OR nuclear medicine OR radionuclide OR radionuclide imaging[sh] OR radiotracer* OR radiopharmaceuticals[mh] OR scintimammogr* OR spectrometry, gamma[mh] OR spectrometry, x-ray emission[mh] OR SPET OR SPECT

AND

artifact* OR artifact* OR attenuate* OR boundar* OR calibration[mh] OR data acquisition OR delineat* OR differentiate* OR dynamic range OR exam time OR field of view OR focal zone OR foreign bodies OR gain setting OR intraobserver[tiab] OR intra-observer[tiab] OR interobserver[tiab] OR inter-observer[tiab] OR interpret* OR kappa OR observer bias OR observer variability OR observer variation[mh] OR reader*[tiab] OR reader concordance OR reverberat* OR shadow* OR speckle reduction OR visuali* OR Accredit* OR Clinical competence[mh] OR experience OR “learning curve” OR learning curve OR “review time” OR review time OR diagnostic errors[mh] OR discomfort* OR “effective dose” OR effective dose OR hazard* OR iatrogenic OR medical errors[mh] OR occupational exposure[mh] OR pain OR patient satisfaction[mh] OR radiation dosage[mh] OR radiation monitoring[mh] OR radiometry[mh] OR safe* OR scintillation counting[mh] OR whole body counting[mh] OR human error OR human factors OR operator error OR timing OR user error OR equipment design[mh:noexp] OR equipment failure[mh:noexp] OR equipment failure analysis[mh] OR equipment reuse[mh] OR equipment safety[mh] OR ambulatory OR facility OR “free-standing” OR “free standing” OR free-standing OR freestanding OR free standing OR mobile OR surgicenter* OR tertiary

NOT

letter[pt] OR editorial[pt] OR news[pt] OR comment[pt] OR case reports[pt] OR review[pt]

TOTAL NUMBER OF ITEMS RETRIEVED: 1042

SEARCH #1B (In-process Records – No MESH Terms Assigned):

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed – 2005–2008

LIMITERS:

English

SEARCH STRATEGY:

breast cancer* OR breast neoplasm*[tiab] OR breast carcinoma* OR breast disease*

AND

diagnosis OR diagnose OR diagnostic OR di[sh] OR “gold standard” OR “ROC” OR “receiver operating characteristic” OR sensitivity and specificity[mh] OR likelihood OR “false positive” OR “false negative” OR “true positive” OR “true negative” OR “predictive value" OR accuracy OR gold standard OR ROC OR receiver operating characteristic OR false positive OR false negative OR true positive OR true negative OR predictive value

AND

(ultrasonography[sh] OR ultrasonography, mammary[mh] OR echogra* OR echomammogr* OR sonogr* OR sonomammogr* OR ultrasound OR ultrason*) OR noninvasive OR non-invasive OR magnetic resonance imaging[mh] OR “magnet strength” OR miraluma OR pulse sequence OR MR OR MRI OR magnet strength OR nuclear magnetic resonance OR NMR OR (FDG* OR fluorodeoxyglucose F 18[mh] OR PET[ti] OR organotechnetium compounds/du[mh] OR positron emission tomography OR sestamibi OR technetium Tc 99m Sestamibi/du[mh] OR tomography, emission-computed[mh] OR tetrofosmin OR gamma camera OR gammagraph* OR nuclear medicine OR radionuclide OR radionuclide imaging[sh] OR radiotracer* OR radiopharmaceuticals[mh] OR scintimammogr* OR spectrometry, gamma[mh] OR spectrometry, x-ray emission[mh] OR SPET OR SPECT

AND

artifact* OR artifact* OR attenuate* OR boundar* OR calibration[mh] OR data acquisition OR delineat* OR differentiate* OR dynamic range OR exam time OR field of view OR focal zone OR foreign bodies OR gain setting OR intraobserver[tiab] OR intra-observer[tiab] OR interobserver[tiab] OR inter-observer[tiab] OR interpret* OR kappa OR observer bias OR observer variability OR observer variation[mh] OR reader*[tiab] OR reader concordance OR reverberat* OR shadow* OR speckle reduction OR visuali* OR Accredit* OR Clinical competence[mh] OR experience OR “learning curve” OR learning curve OR “review time” OR review time OR diagnostic errors[mh] OR discomfort* OR “effective dose” OR effective dose OR hazard* OR iatrogenic OR medical errors[mh] OR occupational exposure[mh] OR pain OR patient satisfaction[mh] OR radiation dosage[mh] OR radiation monitoring[mh] OR radiometry[mh] OR safe* OR scintillation counting[mh] OR whole body counting[mh] OR human error OR human factors OR operator error OR timing OR user error OR equipment design[mh:noexp] OR equipment failure[mh:noexp] OR equipment failure analysis[mh] OR equipment reuse[mh] OR equipment safety[mh] OR ambulatory OR facility OR “free-standing” OR “free standing” OR free-standing OR freestanding OR free standing OR mobile OR surgicenter* OR tertiary

AND

inprocess[sb] OR publisher[sb]

TOTAL NUMBER OF ITEMS RETRIEVED: 54

SEARCH #1C:

DATABASES SEARCHED & TIME PERIOD COVERED:

Database Of Abstracts Of Reviews Of Effects (DARE) – No year limit allowed

Cochrane Database Of Systematic Reviews – 2005–2008

Cochrane Central Register Of Controlled Trials – 2005–2008

SEARCH STRATEGY:

(breast neoplasms or breast diseases or breast disease or breast cancer or breast carcinoma).mp. [mp=ti, ot, ab, sh, hw, kw, tx, ct]

AND

(diagnosis or diagnose or diagnostic or gold standard or ROC or receiver operating characteristic or (sensitivity and specificity) or likelihood or false positive or false negative or true positive or true negative or predictive value).mp.

TOTAL NUMBER OF ITEMS RETRIEVED: 205

TOTAL NUMBER OF RELEVANT ITEMS IDENTIFIED: 81

SEARCH #2 – LIMITED SEARCH:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed – 2005–2008

LIMITERS:

English

SEARCH STRATEGY:

breast neoplasms OR breast diseases[mh] OR breast cancer* OR breast neoplasm*[tiab] OR breast carcinoma* OR breast disease

AND

diagnosis OR diagnose OR diagnostic OR di[sh] OR “gold standard” OR “ROC” OR “receiver operating characteristic” OR sensitivity and specificity[mh] OR likelihood OR “false positive” OR “false negative” OR “true positive” OR “true negative” OR “predictive value" OR accuracy OR gold standard OR ROC OR receiver operating characteristic OR false positive OR false negative OR true positive OR true negative OR predictive value

AND

(ultrasonography[sh] OR ultrasonography, mammary[mh] OR echogra* OR echomammogr* OR sonogr* OR sonomammogr* OR ultrasound OR ultrason*) OR noninvasive OR non-invasive OR magnetic resonance imaging[mh] OR “magnet strength” OR miraluma OR pulse sequence OR MR OR MRI OR magnet strength OR nuclear magnetic resonance OR NMR OR (FDG* OR fluorodeoxyglucose F 18[mh] OR PET[ti] OR organotechnetium compounds/du[mh] OR positron emission tomography OR sestamibi OR technetium Tc 99m Sestamibi/du[mh] OR tomography, emission-computed[mh] OR tetrofosmin OR gamma camera OR gammagraph* OR nuclear medicine OR radionuclide OR radionuclide imaging[sh] OR radiotracer* OR radiopharmaceuticals[mh] OR scintimammogr* OR spectrometry, gamma[mh] OR spectrometry, x-ray emission[mh] OR SPET OR SPECT

AND

artifact* OR artifact* OR attenuate* OR boundar* OR calibration[mh] OR data acquisition OR delineat* OR differentiate* OR dynamic range OR exam time OR field of view OR focal zone OR foreign bodies OR gain setting OR intraobserver[tiab] OR intra-observer[tiab] OR interobserver[tiab] OR inter-observer[tiab] OR interpret* OR kappa OR observer bias OR observer variability OR observer variation[mh] OR reader*[tiab] OR reader concordance OR reverberat* OR shadow* OR speckle reduction OR visuali* OR Accredit* OR Clinical competence[mh] OR experience OR “learning curve” OR learning curve OR “review time” OR review time OR diagnostic errors[mh] OR discomfort* OR “effective dose” OR effective dose OR hazard* OR iatrogenic OR medical errors[mh] OR occupational exposure[mh] OR pain OR patient satisfaction[mh] OR radiation dosage[mh] OR radiation monitoring[mh] OR radiometry[mh] OR safe* OR scintillation counting[mh] OR whole body counting[mh] OR human error OR human factors OR operator error OR timing OR user error OR equipment design[mh:noexp] OR equipment failure[mh:noexp] OR equipment failure analysis[mh] OR equipment reuse[mh] OR equipment safety[mh] OR ambulatory OR facility OR “free-standing” OR “free standing” OR free-standing OR freestanding OR free standing OR mobile OR surgicenter* OR tertiary

AND

"JAMA"[Journal:__jrid5346] OR "N Engl J Med"[Journal:__jrid5985]) OR "Lancet"[Journal:__jrid5470]) OR "Br Med J"[Journal:__jrid1912] OR "Br Med J (Clin Res Ed)"[Journal:__jrid1913] OR "BMJ"[Journal:__jrid2274]) OR "Ann Intern Med"[Journal:__jrid596]) OR "CA Cancer J Clin"[Journal:__jrid2683]) OR "Radiol Clin North Am"[Journal:__jrid6854]) OR "J Nucl Med"[Journal:__jrid5045]) OR "Eur J Nucl Med"[Journal:__jrid3620]) OR "Radiology"[Journal:__jrid6859]) OR "J Magn Reson Imaging"[Journal:__jrid2081]) OR "J Ultrasound Med"[Journal:__jrid5330]

TOTAL NUMBER OF ITEMS RETRIEVED: 297

## CER 3 – EPOETIN UPDATE: SEARCH METHODOLOGY

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2005–2008

SEARCH STRATEGY:

erythropoietin OR epoetin* OR epo OR eprex OR neorecormon OR aranesp OR procrit OR darbepoetin OR erythropoietin[mh] OR erythropoietin, recombinant[mh] OR epoetin alfa[mh] OR epoetin beta[substance name] OR darbepoetin alfa[mh] OR darbepoetin alfa[substance name}

AND

"JAMA"[Journal:__jrid5346] OR "N Engl J Med"[Journal:__jrid5985] OR "Lancet"[Journal:__jrid5470] OR "Br Med J"[Journal:__jrid1912] OR "Br Med J (Clin Res Ed)"[Journal:__jrid1913] OR "BMJ"[Journal:__jrid2274] OR "Ann Intern Med"[Journal:__jrid596] OR ("Ann Oncol"[Journal:__jrid1846] OR "Br J Cancer"[Journal:__jrid1765] OR "Br J Cancer Suppl"[Journal:__jrid1766] OR "J Clin Oncol"[Journal:__jrid5023] OR "Oncology"[Journal:__jrid6265] OR "Oncology (Williston Park)"[Journal:__jrid1783]) OR "Cancer"[Journal:__jrid2771]

AND

randomized controlled trials[mh] OR randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt]

AND

randomized controlled trial* OR randomized controlled trials OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt]) OR (triple blind* OR triple-blind* OR single blind* OR single-blind* OR double blind* OR double-blind* OR treble blind* OR treble-blind* OR placebo)

TOTAL NUMBER OF ITEMS RETRIEVED: 94

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane DARE – No date limit allowed

SEARCH STRATEGY:

erythropoietin OR epoetin* OR epo OR eprex OR neorecormon OR aranesp OR procrit OR darbepoetin {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 3

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Database of Systematic Reviews – 2005–2008

SEARCH STRATEGY:

erythropoietin OR epoetin* OR epo OR eprex OR neorecormon OR aranesp OR procrit OR darbepoetin {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 1

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Central (Controlled Trials Register) – 2005–2008

SEARCH STRATEGY:

erythropoietin OR epoetin* OR epo OR eprex OR neorecormon OR aranesp OR procrit OR darbepoetin {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 13

## CER 4 – OSTEOARTHRITIS/ANALGESICS – 2008 UPDATE: SEARCH METHODOLOGY

SEARCH #1A:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2005–2008

LIMITERS:

English

Human

SEARCH STRATEGY:

"osteoarthritis"[MeSH Terms] OR "osteoarthritis"[All Fields]

AND

"JAMA"[Journal:__jrid5346] OR "N Engl J Med"[Journal:__jrid5985] OR "Lancet"[Journal:__jrid5470] OR "Br Med J"[Journal:__jrid1912] OR "Br Med J (Clin Res Ed)"[Journal:__jrid1913] OR "BMJ"[Journal:__jrid2274] OR "Ann Intern Med"[Journal:__jrid596] OR "Rheumatology"[Journal:__jrid7289] OR "Rheumatology (Oxford)"[Journal:__jrid21385] OR "J Pain"[Journal:__jrid31708] OR "Pain"[Journal:__jrid6347] OR "Br J Rheumatol"[Journal:__jrid1901] OR "J Rheumatol"[Journal:__jrid5243] OR "J Rheumatol Suppl"[Journal:__jrid5244] OR "Arthritis Rheum"[Journal:__jrid881]

AND

celecoxib or choline magnesium trisalicylate or diclofenac or diflunisal or etodolac or fenoprofen or flurbiprofen or ibuprofen or indomethacin or ketoprofen or ketorolac or meclofenamate sodium or mefenamic acid or meloxicam or nabumetone or naproxen or oxaprozin or piroxicam or salsalate or sulindac or tolmetin or valdecoxib

AND

randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt]

TOTAL NUMBER OF ITEMS RETRIEVED: 19

SEARCH #1B:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2005–2008

LIMITERS:

English

Human

SEARCH STRATEGY:

"Arthritis, Rheumatoid"[Mesh]

AND

"JAMA"[Journal:__jrid5346] OR "N Engl J Med"[Journal:__jrid5985] OR "Lancet"[Journal:__jrid5470] OR "Br Med J"[Journal:__jrid1912] OR "Br Med J (Clin Res Ed)"[Journal:__jrid1913] OR "BMJ"[Journal:__jrid2274] OR "Ann Intern Med"[Journal:__jrid596] OR "Rheumatology"[Journal:__jrid7289] OR "Rheumatology (Oxford)"[Journal:__jrid21385] OR "J Pain"[Journal:__jrid31708] OR "Pain"[Journal:__jrid6347] OR "Br J Rheumatol"[Journal:__jrid1901] OR "J Rheumatol"[Journal:__jrid5243] OR "J Rheumatol Suppl"[Journal:__jrid5244] OR "Arthritis Rheum"[Journal:__jrid881]

AND

celecoxib or choline magnesium trisalicylate or diclofenac or diflunisal or etodolac or fenoprofen or flurbiprofen or ibuprofen or indomethacin or ketoprofen or ketorolac or meclofenamate sodium or mefenamic acid or meloxicam or nabumetone or naproxen or oxaprozin or piroxicam or salsalate or sulindac or tolmetin or valdecoxib

AND

randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt]

TOTAL NUMBER OF ITEMS RETRIEVED: 8

SEARCH #1C:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2005–2008

LIMITERS:

English

Human

SEARCH STRATEGY:

"osteoarthritis"[MeSH Terms] OR "osteoarthritis"[All Fields] OR "Arthritis, Rheumatoid"[Mesh]

AND

"JAMA"[Journal:__jrid5346] OR "N Engl J Med"[Journal:__jrid5985] OR "Lancet"[Journal:__jrid5470] OR "Br Med J"[Journal:__jrid1912] OR "Br Med J (Clin Res Ed)"[Journal:__jrid1913] OR "BMJ"[Journal:__jrid2274] OR "Ann Intern Med"[Journal:__jrid596] OR "Rheumatology"[Journal:__jrid7289] OR "Rheumatology (Oxford)"[Journal:__jrid21385] OR "J Pain"[Journal:__jrid31708] OR "Pain"[Journal:__jrid6347] OR "Br J Rheumatol"[Journal:__jrid1901] OR "J Rheumatol"[Journal:__jrid5243] OR "J Rheumatol Suppl"[Journal:__jrid5244] OR "Arthritis Rheum"[Journal:__jrid881]

AND

aspirin OR acetaminophen

AND

randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt]

TOTAL NUMBER OF ITEMS RETRIEVED: 18

SEARCH #1D:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2005–2008

LIMITERS:

English

Human

SEARCH STRATEGY:

"osteoarthritis"[MeSH Terms] OR "osteoarthritis"[All Fields]

AND

"JAMA"[Journal:__jrid5346] OR "N Engl J Med"[Journal:__jrid5985] OR "Lancet"[Journal:__jrid5470] OR "Br Med J"[Journal:__jrid1912] OR "Br Med J (Clin Res Ed)"[Journal:__jrid1913] OR "BMJ"[Journal:__jrid2274] OR "Ann Intern Med"[Journal:__jrid596] OR "Rheumatology"[Journal:__jrid7289] OR "Rheumatology (Oxford)"[Journal:__jrid21385] OR "J Pain"[Journal:__jrid31708] OR "Pain"[Journal:__jrid6347] OR "Br J Rheumatol"[Journal:__jrid1901] OR "J Rheumatol"[Journal:__jrid5243] OR "J Rheumatol Suppl"[Journal:__jrid5244] OR "Arthritis Rheum"[Journal:__jrid881]

AND

topical AND (capsaicin OR diclofenac OR ibuprofen OR ketoprofen OR salicylate)

AND

randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt]

TOTAL NUMBER OF ITEMS RETRIEVED: 4

## CER 6 – ATYPICAL ANTIPSYCHOTICS – 2008 UPDATE: SEARCH METHODOLOGY

SEARCH #1A – SYSTEMATIC REVIEWS & OTHER EVIDENCE-BASED SOURCES:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

SEARCH STRATEGY:

Antipsychotic Agents[mh] OR Antipsychotic Agents[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone

AND

depression OR dementia OR obsessive compulsive disorder OR post traumatic stress disorder OR ptsd OR off label OR off-label

AND

systematic review*

TOTAL NUMBER OF ITEMS RETRIEVED: 18

SEARCH #1B – SYSTEMATIC REVIEWS & OTHER EVIDENCE-BASED SOURCES:

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane DARE

SEARCH STRATEGY:

Antipsychotic Agents OR ziprasidone OR Risperidone OR olanzapine OR quetiapine OR aripiprazole OR antipsychotic OR antipsychotics OR anti-psychotic OR anti-psychotics {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 32

SEARCH #1C – SYSTEMATIC REVIEWS & OTHER EVIDENCE-BASED SOURCES:

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Systematic Reviews Database

SEARCH STRATEGY:

Antipsychotic Agents OR ziprasidone OR Risperidone OR olanzapine OR quetiapine OR aripiprazole OR antipsychotic OR antipsychotics OR anti-psychotic OR anti-psychotics {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 16

SEARCH #1D – SYSTEMATIC REVIEWS & OTHER EVIDENCE-BASED SOURCES:

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Central (Controlled Trials Register) – 2006–2008

SEARCH STRATEGY:

Antipsychotic Agents OR ziprasidone OR Risperidone OR olanzapine OR quetiapine OR aripiprazole OR antipsychotic OR antipsychotics OR anti-psychotic OR anti-psychotics {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 88

SEARCH #1E – SYSTEMATIC REVIEWS & OTHER EVIDENCE-BASED SOURCES:

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane – All databases – 2006–2008 (No date limit allowed in DARE)

SEARCH STRATEGY:

(Antipsychotic Agents OR ziprasidone OR Risperidone OR olanzapine OR quetiapine OR aripiprazole OR antipsychotic OR antipsychotics OR anti-psychotic OR anti-psychotics).mp. [mp=ti, ot, ab, sh, hw, kw, tx, ct] (Note – Related terms included)

AND

(atypical or off label or non intended or non intentional).mp.

TOTAL NUMBER OF ITEMS RETRIEVED: 224

SEARCH #2A – OFF-LABEL + SPECIFIC DRUGS + CONDITIONS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

SEARCH STRATEGY:

“atypical use” OR “off label” OR “non intended” OR “non intentional” OR atypical use OR off label OR non intended OR non intentional

AND

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR risperidone[mh] OR olanzapine[Substance Name] OR quetiapine[Substance Name] OR aripiprazole[Substance Name] OR ziprasidone[Substance Name]

AND

“Personality Disorders”[mh] OR “Dementia”[mh] OR “Depression”[mh] OR “Depressive Disorder”[mh] OR “Obsessive-Compulsive Disorder”[mh] OR “Stress Disorders, Post-Traumatic”[mh] OR “Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation OR Personality Disorders[mh] OR Dementia[mh] OR Depression[mh] OR depressive Disorder[mh] OR Obsessive-Compulsive Disorder[mh] OR Stress Disorders, Post-Traumatic[mh] OR Personality Disorder* OR Dementia OR Depression OR depressive Disorder OR depress* OR Obsessive Compulsive Disorder OR ocd OR Post-Traumatic Stress disorder* OR ptsd OR severe geriatric agitation OR geriatric agitation

TOTAL NUMBER OF ITEMS RETRIEVED: 190

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

(kw: off w label) OR kw: off-label OR kw: offlabel OR (kw: atypical w use) OR (kw: non w intended w use) OR (kw: non w intentional w use) OR (kw: “not” w intended w use)

AND

kw: Risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone or de: Risperidone OR de: olanzapine OR de: quetiapine OR de: aripiprazole OR de: ziprasidone

AND

su= “personality disorders” OR su= “obsessive compulsive disorder” OR su= “obsessive compulsive personality disorder” OR su= “posttraumatic stress disorder” or su: dementia OR su: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation) OR (kw: personality w disorders) OR (kw: obsessive w compulsive w disorder) OR (kw: obsessive w compulsive w personality w disorder) OR (kw: posttraumatic w stress w disorder) OR kw: ptsd OR kw: ocd OR (kw: post w traumatic w stress) OR (kw: obsessive w compulsive) or kw: dementia OR kw: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation)

TOTAL NUMBER OF ITEMS RETRIEVED: 6

SEARCH #2B – OFF-LABEL + SPECIFIC DRUGS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

SEARCH STRATEGY:

“atypical use” OR “off label” OR “non intended” OR “non intentional” OR atypical use OR off label OR non intended OR non intentional

AND

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR risperidone[mh] OR olanzapine[Substance Name] OR quetiapine[Substance Name] OR aripiprazole[Substance Name] OR ziprasidone[Substance Name]

TOTAL NUMBER OF ITEMS RETRIEVED: 826

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

(kw: off w label) OR kw: off-label OR kw: offlabel OR (kw: atypical w use) OR (kw: non w intended w use) OR (kw: non w intentional w use) OR (kw: “not” w intended w use)

kw: Risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone or de: Risperidone OR de: olanzapine OR de: quetiapine OR de: aripiprazole OR de: ziprasidone

TOTAL NUMBER OF ITEMS RETRIEVED: 12

SEARCH #2C – OFF-LABEL + SPECIFIC CONDITIONS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

SEARCH STRATEGY:

“atypical use” OR “off label” OR “non intended” OR “non intentional” OR atypical use OR off label OR non intended OR non intentional

AND

“Personality Disorders”[mh] OR “Dementia”[mh] OR “Depression”[mh] OR “Depressive Disorder”[mh] OR “Obsessive-Compulsive Disorder”[mh] OR “Stress Disorders, Post-Traumatic”[mh] OR “Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation OR Personality Disorders[mh] OR Dementia[mh] OR Depression[mh] OR depressive Disorder[mh] OR Obsessive-Compulsive Disorder[mh] OR Stress Disorders, Post-Traumatic[mh] OR Personality Disorder* OR Dementia OR Depression OR depressive Disorder OR depress* OR Obsessive Compulsive Disorder OR ocd OR Post-Traumatic Stress disorder* OR ptsd OR severe geriatric agitation OR geriatric agitation

TOTAL NUMBER OF ITEMS RETRIEVED: 719

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

(kw: off w label) OR kw: off-label OR kw: offlabel OR (kw: atypical w use) OR (kw: non w intended w use) OR (kw: non w intentional w use) OR (kw: “not” w intended w use)

su= “personality disorders” OR su= “obsessive compulsive disorder” OR su= “obsessive compulsive personality disorder” OR su= “posttraumatic stress disorder” or su: dementia OR su: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation) OR (kw: personality w disorders) OR (kw: obsessive w compulsive w disorder) OR (kw: obsessive w compulsive w personality w disorder) OR (kw: posttraumatic w stress w disorder) OR kw: ptsd OR kw: ocd OR (kw: post w traumatic w stress) OR (kw: obsessive w compulsive) or kw: dementia OR kw: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation)

TOTAL NUMBER OF ITEMS RETRIEVED: 29

SEARCH #2D – SPECIFIC DRUGS + CONDITIONS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

SEARCH STRATEGY:

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR risperidone[mh] OR olanzapine[Substance Name] OR quetiapine[Substance Name] OR aripiprazole[Substance Name] OR ziprasidone[Substance Name]

AND

“Personality Disorders”[mh] OR “Dementia”[mh] OR “Depression”[mh] OR “Depressive Disorder”[mh] OR “Obsessive-Compulsive Disorder”[mh] OR “Stress Disorders, Post-Traumatic”[mh] OR “Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation OR Personality Disorders[mh] OR Dementia[mh] OR Depression[mh] OR depressive Disorder[mh] OR Obsessive-Compulsive Disorder[mh] OR Stress Disorders, Post-Traumatic[mh] OR Personality Disorder* OR Dementia OR Depression OR depressive Disorder OR depress* OR Obsessive Compulsive Disorder OR ocd OR Post-Traumatic Stress disorder* OR ptsd OR severe geriatric agitation OR geriatric agitation

TOTAL NUMBER OF ITEMS RETRIEVED: 551

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

kw: Risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone or de: Risperidone OR de: olanzapine OR de: quetiapine OR de: aripiprazole OR de: ziprasidone

AND

su= “personality disorders” OR su= “obsessive compulsive disorder” OR su= “obsessive compulsive personality disorder” OR su= “posttraumatic stress disorder” or su: dementia OR su: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation) OR (kw: personality w disorders) OR (kw: obsessive w compulsive w disorder) OR (kw: obsessive w compulsive w personality w disorder) OR (kw: posttraumatic w stress w disorder) OR kw: ptsd OR kw: ocd OR (kw: post w traumatic w stress) OR (kw: obsessive w compulsive) or kw: dementia OR kw: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation)

TOTAL NUMBER OF ITEMS RETRIEVED: 391

SEARCH #2E – SPECIFIC DRUGS + CONDITIONS + CLINICAL TRIALS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

kw: Risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone or de: Risperidone OR de: olanzapine OR de: quetiapine OR de: aripiprazole OR de: ziprasidone

AND

su= “personality disorders” OR su= “obsessive compulsive disorder” OR su= “obsessive compulsive personality disorder” OR su= “posttraumatic stress disorder” or su: dementia OR su: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation) OR (kw: personality w disorders) OR (kw: obsessive w compulsive w disorder) OR (kw: obsessive w compulsive w personality w disorder) OR (kw: posttraumatic w stress w disorder) OR kw: ptsd OR kw: ocd OR (kw: post w traumatic w stress) OR (kw: obsessive w compulsive) or kw: dementia OR kw: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation)

AND

de= “clinical trials” OR (kw: controlled w clinical w trial) OR (kw: controlled w clinical w trials) OR (kw: randomized w trial) OR (kw: randomized w trials) OR (kw: randomized w controlled w trial) OR (kw: randomized w controlled w trials) OR (kw: clinical w trial) OR (kw: clincal w trials)

TOTAL NUMBER OF ITEMS RETRIEVED: 53

SEARCH #2F – SPECIFIC DRUGS + CONDITIONS + CLINICAL TRIALS + OFF-LABEL:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

kw: Risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone or de: Risperidone OR de: olanzapine OR de: quetiapine OR de: aripiprazole OR de: ziprasidone

AND

su= “personality disorders” OR su= “obsessive compulsive disorder” OR su= “obsessive compulsive personality disorder” OR su= “posttraumatic stress disorder” or su: dementia OR su: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation) OR (kw: personality w disorders) OR (kw: obsessive w compulsive w disorder) OR (kw: obsessive w compulsive w personality w disorder) OR (kw: posttraumatic w stress w disorder) OR kw: ptsd OR kw: ocd OR (kw: post w traumatic w stress) OR (kw: obsessive w compulsive) or kw: dementia OR kw: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation)

AND

de= “clinical trials” OR (kw: controlled w clinical w trial) OR (kw: controlled w clinical w trials) OR (kw: randomized w trial) OR (kw: randomized w trials) OR (kw: randomized w controlled w trial) OR (kw: randomized w controlled w trials) OR (kw: clinical w trial) OR (kw: clincal w trials)

AND

(kw: off w label) OR kw: off-label OR kw: offlabel OR (kw: atypical w use) OR (kw: non w intended w use) OR (kw: non w intentional w use) OR (kw: “not” w intended w use)

TOTAL NUMBER OF ITEMS RETRIEVED: 1

SEARCH #2G – OFF-LABEL + GENERAL ATYPICAL ANTIPSYCHOTICS TERMS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

(kw: off w label) OR kw: off-label OR kw: offlabel OR (kw: atypical w use) OR (kw: non w intended w use) OR (kw: non w intentional w use) OR (kw: “not” w intended w use)

AND

((kw: atypical and (kw: antipsychotic* OR kw: anti-psychotic*))

NOT

(kw: Risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone or de: Risperidone OR de: olanzapine OR de: quetiapine OR de: aripiprazole OR de: ziprasidone)

TOTAL NUMBER OF ITEMS RETRIEVED: 10

SEARCH #2H – GENERAL ATYPICAL ANTIPSYCHOTICS TERMS + CONDITIONS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

kw: atypical and (kw: antipsychotic* OR kw: anti-psychotic*)

AND

su= “personality disorders” OR su= “obsessive compulsive disorder” OR su= “obsessive compulsive personality disorder” OR su= “posttraumatic stress disorder” or su: dementia OR su: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation) OR (kw: personality w disorders) OR (kw: obsessive w compulsive w disorder) OR (kw: obsessive w compulsive w personality w disorder) OR (kw: posttraumatic w stress w disorder) OR kw: ptsd OR kw: ocd OR (kw: post w traumatic w stress) OR (kw: obsessive w compulsive) or kw: dementia OR kw: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation)

NOT

kw: Risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone or de: Risperidone OR de: olanzapine OR de: quetiapine OR de: aripiprazole OR de: ziprasidone

TOTAL NUMBER OF ITEMS RETRIEVED: 112

SEARCH #2I – GENERAL ATYPICAL ANTIPSYCHOTICS TERMS + CONDITIONS + CLINICAL TRIALS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

SEARCH STRATEGY:

kw: atypical and (kw: antipsychotic* OR kw: anti-psychotic*)

AND

su= “personality disorders” OR su= “obsessive compulsive disorder” OR su= “obsessive compulsive personality disorder” OR su= “posttraumatic stress disorder” or su: dementia OR su: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation) OR (kw: personality w disorders) OR (kw: obsessive w compulsive w disorder) OR (kw: obsessive w compulsive w personality w disorder) OR (kw: posttraumatic w stress w disorder) OR kw: ptsd OR kw: ocd OR (kw: post w traumatic w stress) OR (kw: obsessive w compulsive) or kw: dementia OR kw: depression OR (kw: severe w geriatric w agitation) OR (kw: geriatric w agitation)

AND

de= “clinical trials” OR (kw: controlled w clinical w trial) OR (kw: controlled w clinical w trials) OR (kw: randomized w trial) OR (kw: randomized w trials) OR (kw: randomized w controlled w trial) OR (kw: randomized w controlled w trials) OR (kw: clinical w trial) OR (kw: clincal w trials)

TOTAL NUMBER OF ITEMS RETRIEVED: 8

SEARCH #3A – LIMITED SEARCH:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

Letter

Editorial

Comment

SEARCH STRATEGY:

annals of internal medicine OR british medical journal OR jama OR lancet OR new england journal of medicine OR archives of general psychiatry OR american journal of psychiatry

AND

Antipsychotic Agents[mh] OR Antipsychotic Agents[Pharmacological Action] OR Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR Risperidone[mh] OR olanzapine[Substance Name] OR quetiapine[Substance Name] OR aripiprazole[Substance Name] OR ziprasidone[Substance Name]

OR

annals of internal medicine OR british medical journal OR jama OR lancet OR new england journal of medicine OR archives of general psychiatry OR american journal of psychiatry

AND

atypical use OR off label OR non intended OR non intentional

AND

Personality Disorders[mh] OR Dementia[mh] OR Depression[mh] OR depressive Disorder[mh] OR Obsessive-Compulsive Disorder[mh] OR Stress Disorders, Post-Traumatic[mh] OR Personality Disorder* OR Dementia OR Depression OR depressive Disorder OR depress* OR Obsessive Compulsive Disorder OR ocd OR Post-Traumatic Stress disorder* OR ptsd OR severe geriatric agitation OR geriatric agitation OR “Personality Disorders”[mh] OR “Dementia”[mh] OR “Depression”[mh] OR “Depressive Disorder”[mh] OR “Obsessive-Compulsive Disorder”[mh] OR “Stress Disorders, Post-Traumatic”[mh] OR “Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation

TOTAL NUMBER OF ITEMS RETRIEVED: 104

SEARCH #3B – LIMITED SEARCH (Revision – Includes all publication types):

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

SEARCH STRATEGY: (Note – Journals were searched using the PubMed Journals Database)

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] OR “Arch Gen Psychiatry”[Journal:__jrid744] OR american journal of psychiatry[ta]

AND

Antipsychotic Agents[mh] OR Antipsychotic Agents[Pharmacological Action] OR Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR Risperidone[mh] OR olanzapine[Substance Name] OR quetiapine[Substance Name] OR aripiprazole[Substance Name] OR ziprasidone[Substance Name] OR antipsychotic* OR anti-psychotic*

OR

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] OR “Arch Gen Psychiatry”[Journal:__jrid744] OR american journal of psychiatry[ta]

AND

atypical use OR off label OR non intended OR non intentional

AND

Personality Disorders[mh] OR Dementia[mh] OR Depression[mh] OR depressive Disorder[mh] OR Obsessive-Compulsive Disorder[mh] OR Stress Disorders, Post-Traumatic[mh] OR Personality Disorder* OR Dementia OR Depression OR depressive Disorder OR depress* OR Obsessive Compulsive Disorder OR ocd OR Post-Traumatic Stress disorder* OR ptsd OR severe geriatric agitation OR geriatric agitation OR “Personality Disorders”[mh] OR “Dementia”[mh] OR “Depression”[mh] OR “Depressive Disorder”[mh] OR “Obsessive-Compulsive Disorder”[mh] OR “Stress Disorders, Post-Traumatic”[mh] OR “Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation

TOTAL NUMBER OF ITEMS RETRIEVED: 265

SEARCH #3C – LIMITED SEARCH (Revision - Add RCT’s):

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

Letter

Editorial

Comment

Randomized Controlled Trial

SEARCH STRATEGY: (Note – Journals were searched using the PubMed Journals Database)

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] OR “Arch Gen Psychiatry”[Journal:__jrid744] OR american journal of psychiatry[ta]

AND

Antipsychotic Agents[mh] OR Antipsychotic Agents[Pharmacological Action] OR Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR Risperidone[mh] OR olanzapine[Substance Name] OR quetiapine[Substance Name] OR aripiprazole[Substance Name] OR ziprasidone[Substance Name] OR antipsychotic* OR anti-psychotic*

AND

Personality Disorders[mh] OR Dementia[mh] OR Depression[mh] OR depressive Disorder[mh] OR Obsessive-Compulsive Disorder[mh] OR Stress Disorders, Post-Traumatic[mh] OR Personality Disorder* OR Dementia OR Depression OR depressive Disorder OR depress* OR Obsessive Compulsive Disorder OR ocd OR Post-Traumatic Stress disorder* OR ptsd OR severe geriatric agitation OR geriatric agitation OR “Personality Disorders”[mh] OR “Dementia”[mh] OR “Depression”[mh] OR “Depressive Disorder”[mh] OR “Obsessive-Compulsive Disorder”[mh] OR “Stress Disorders, Post-Traumatic”[mh] OR “Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation

AND

atypical use OR atypical[tiab] OR off label OR offlabel OR non intended OR non intentional OR non-intended OR non-intentional

AND

randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR

TOTAL NUMBER OF ITEMS RETRIEVED: 265

SEARCH #3D – LIMITED SEARCH:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

LIMITERS:

Letter

Editorial

Comment

SEARCH STRATEGY:

so: bmj OR (so: annals and so: internal and so: medicine) OR (so: british and so: medical and so: journal) OR so: jama OR so: lancet OR (so: new and so: england and so: journal and so: medicine) OR (so: archives and so: general and so: psychiatry) OR (so: american and so: journal and so: psychiatry)

AND

kw: risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone OR (kw: atypical and kw: antipsychotic*) OR (kw: atypical and kw: anti-psychotic*)

TOTAL NUMBER OF ITEMS RETRIEVED: 28

SEARCH #3F – LIMITED SEARCH (Revision - Add RCT’s):

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

LIMITERS:

Letter

Editorial

Comment

Randomized Controlled Trials

SEARCH STRATEGY:

so: bmj OR (so: annals and so: internal and so: medicine) OR (so: british and so: medical and so: journal) OR so: jama OR so: lancet OR (so: new and so: england and so: journal and so: medicine) OR (so: archives and so: general and so: psychiatry) OR (so: american and so: journal and so: psychiatry)

AND

kw: risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone OR (kw: atypical and kw: antipsychotic*) OR (kw: atypical and kw: anti-psychotic*)

AND

(kw: Personality and kw: Disorder*) OR kw: Dementia OR kw: Depress* OR kw: Obsessive-Compulsive OR (kw: obsessive and kw: compulsive) OR kw: ocd OR (kw: post and kw: traumatic and kw: stress) OR kw: ptsd OR (kw: geriatric and kw: agitat*)

AND

kw: atypical OR (kw: off and kw: label) OR kw: offlabel OR (kw: non and kw: intended) OR kw: non-intended OR (kw: non and kw: intentional) OR kw: non-intentional

AND

(kw: randomized and kw: controlled and kw: trial*) OR kw: rct* OR (kw: random and kw: allocation) OR kw: randomi* OR (kw: double and kw: blind) OR kw: double-blind OR (kw: single and kw: blind) OR kw: single-blind OR kw: letter* OR kw: editorial* OR kw: comment*

TOTAL NUMBER OF ITEMS RETRIEVED: 130

## CER 7 - ANTIDEPRESSIVE AGENTS – 2008 UPDATE: SEARCH METHODOLOGY

SEARCH #1A – GENERAL TOPIC:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

OTHER LIMITERS:

English

Human

Adult (19 years+)

SEARCH STRATEGY:

“antidepressive agents, second-generation”[mh] OR “fluoxetine”[mh] OR “sertraline”[mh] OR “paroxetine”[mh] OR “citalopram”[mh] OR “fluvoxamine”[mh] OR “bupropion”[mh] OR “nefazodone”[nm] OR “mirtazapine”[nm] OR “venlafaxine”[nm] OR “escitalopram”[tw] OR “duloxetine”[nm] OR “trazodone”[mh] OR antidepressive agents, second-generation OR fluoxetine[mh] OR sertraline[mh] OR paroxetine[mh] OR citalopram[mh] OR fluvoxamine[mh] OR bupropion[mh] OR nefazodone[nm] OR mirtazapine[nm] OR venlafaxine[nm] OR escitalopram OR duloxetine[nm] OR trazodone[mh]

AND

“depressive disorder”[mh] OR “depressive disorder, major”[mh] OR “depression, involutional”[tw] OR “dysthymic disorder”[mh] OR “subsyndronal depressive disorder”[tw] OR depressive disorder[mh] OR depressive disorder, major[mh] OR depression, involutional[tw] OR dysthymic disorder[mh] OR subsyndronal depressive disorder[tw]

AND

“quality of life”[mh] OR “hospitalization”[mh] OR quality of life[mh] OR hospitalization[mh]

NOT

“randomized controlled trial”[pt] OR “randomized controlled trials”[mh] OR “single-blind method”[mh] OR “double-blind method”[mh] OR “random allocation”[mh] OR randomized controlled trial[pt] OR randomized controlled trials[mh] OR single-blind method[mh] OR double-blind method[mh] OR random allocation[mh]

TOTAL NUMBER OF ITEMS RETRIEVED: 8

SEARCH #1B – GENERAL TOPIC:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO – 2006–2008

OTHER LIMITERS:

English

Human

SEARCH STRATEGY:

su= “antidepressant drugs” OR de= “antidepressant drugs” OR kw: fluoxetine OR kw: sertraline OR kw: paroxetine OR kw: citalopram OR kw: fluvoxamine OR kw: bupropion OR kw: nefazodone OR kw: mirtazapine OR kw: venlafaxine OR kw: escitalopram OR kw: duloxetine OR kw: trazodone

AND

de: depressi* OR su: depressi* OR kw: dysthymi*

AND

(kw: quality AND kw: life) OR kw: hospitaliz* OR kw: hospitalis*

NOT

kw: random* OR kw: single-blind* OR (kw: single AND kw: blind*) OR kw: double-blind* OR (kw: double AND kw: blind*)

TOTAL NUMBER OF ITEMS RETRIEVED: 45

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane – All databases

OTHER LIMITERS:

English

Human

SEARCH STRATEGY:

(fluoxetine or sertraline or paroxetine or citalopram or fluvoxamine or bupropion or nefazodone or mirtazapine or venlafaxine or escitalopram or duloxetine or trazodone).mp. OR antidepressive agents, second-generation.mp.

AND

(depression or depressive or depressed).ti,sh,hw.

TOTAL NUMBER OF ITEMS RETRIEVED: 484

SEARCH #2A – ADVERSE EVENTS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

OTHER LIMITERS:

English

Human

Adult (19 years+)

SEARCH STRATEGY:

“antidepressive agents, second-generation”[mh] OR “fluoxetine”[mh] OR “sertraline”[mh] OR “paroxetine”[mh] OR “citalopram”[mh] OR “fluvoxamine”[mh OR “bupropion”[mh] OR “nefazodone”[nm] OR “mirtazapine”[nm] OR “venlafaxine”[nm] OR “escitalopram”[tw] OR “duloxetine”[nm] OR “trazodone”[mh] OR antidepressive agents, second-generation OR fluoxetine[mh] OR sertraline[mh] OR paroxetine[mh] OR citalopram[mh] OR fluvoxamine[mh] OR bupropion[mh] OR nefazodone[nm] OR mirtazapine[nm] OR venlafaxine[nm] OR escitalopram OR duloxetine[nm] OR trazodone[mh]

AND

“depressive disorder”[mh] OR “depressive disorder, major”[mh] OR “depression, involutional”[tw] OR “dysthymic disorder”[mh] OR “subsyndronal depressive disorder”[tw] OR depressive disorder[mh] OR depressive disorder, major[mh] OR depression, involutional[tw] OR dysthymic disorder[mh] OR subsyndronal depressive disorder[tw]

AND

“adverse events”[tw] OR “drug hypersensitivity”[mh] OR “drug toxicity”[mh] OR hyponatremia[mh] OR seizures[mh] OR suicide[mh] OR “weight gain”[mh] OR “gastroesophageal reflux”[mh] OR libido[mh] OR hepatoxicity[tw] OR adverse events[tw] OR drug hypersensitivity[mh] OR drug toxicity[mh] OR hyponatremia[mh] OR seizures[mh] OR suicide[mh] OR weight gain[mh] OR gastroesophageal reflux[mh] OR libido[mh] OR hepatoxicity[tw]

NOT

“randomized controlled trial”[pt] OR “randomized controlled trials”[mh] OR “single-blind method”[mh] OR “double-blind method”[mh] OR “random allocation”[mh] OR randomized controlled trial[pt] OR randomized controlled trials[mh] OR single-blind method[mh] OR double-blind method[mh] OR random allocation[mh]

TOTAL NUMBER OF ITEMS RETRIEVED: 58

SEARCH #2B – ADVERSE EVENTS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO – 2006–2008

OTHER LIMITERS:

English

SEARCH STRATEGY:

su= “antidepressant drugs” OR de= “antidepressant drugs” OR kw: fluoxetine OR kw: sertraline OR kw: paroxetine OR kw: citalopram OR kw: fluvoxamine OR kw: bupropion OR kw: nefazodone OR kw: mirtazapine OR kw: venlafaxine OR kw: escitalopram OR kw: duloxetine OR kw: trazodone

AND

de: depressi* OR su: depressi* OR kw: dysthymi*

AND

kw: side w effect OR kw: side w effects) OR (kw: adverse or kw: hypersensitiv* OR kw: toxic* OR kw: hyponatremi* OR kw: seizure* OR kw: suicid* OR kw: weight OR kw: reflux OR kw: libido OR kw: hepatoxic*

NOT

kw: random* OR kw: single-blind* OR (kw: single AND kw: blind*) OR kw: double-blind* OR (kw: double AND kw: blind*)

TOTAL NUMBER OF ITEMS RETRIEVED: 288

SEARCH #3A – LONGITUDINAL STUDIES:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

OTHER LIMITERS:

English

Human

Adult (19 years+)

SEARCH STRATEGY:

“antidepressive agents, second-generation”[mh] OR “fluoxetine”[mh] OR “sertraline”[mh] OR “paroxetine”[mh] OR “citalopram”[mh] OR “fluvoxamine”[mh OR “bupropion”[mh] OR “nefazodone”[nm] OR “mirtazapine”[nm] OR “venlafaxine”[nm] OR “escitalopram”[tw] OR “duloxetine”[nm] OR “trazodone”[mh] OR antidepressive agents, second-generation OR fluoxetine[mh] OR sertraline[mh] OR paroxetine[mh] OR citalopram[mh] OR fluvoxamine[mh] OR bupropion[mh] OR nefazodone[nm] OR mirtazapine[nm] OR venlafaxine[nm] OR escitalopram OR duloxetine[nm] OR trazodone[mh]

AND

“depressive disorder”[mh] OR “depressive disorder, major”[mh] OR “depression, involutional”[tw] OR “dysthymic disorder”[mh] OR “subsyndronal depressive disorder”[tw] OR depressive disorder[mh] OR depressive disorder, major[mh] OR depression, involutional[tw] OR dysthymic disorder[mh] OR subsyndronal depressive disorder[tw]

AND

longitudinal studies[mh] OR cohort studies[mh] OR case-control studies[mh] OR comparative study[pt] OR “observational studies”[tw] OR longitudinal studies[mh] OR cohort studies[mh] OR case-control studies[mh] OR comparative study[pt] OR observational studies[tw]

NOTE: ORIGINAL SEARCH USED COMPARATIVE STUDY AS A MESH TERM[MH]; SHOULD HAVE BEEN PUBLICATION TYPE[PT]

NOT

“randomized controlled trial”[pt] OR “randomized controlled trials”[mh] OR “single-blind method”[mh] OR “double-blind method”[mh] OR “random allocation”[mh] OR randomized controlled trial[pt] OR randomized controlled trials[mh] OR single-blind method[mh] OR double-blind method[mh] OR random allocation[mh]

TOTAL NUMBER OF ITEMS RETRIEVED: 102

SEARCH #3B – LONGITUDINAL STUDIES:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO – 2006–2008

OTHER LIMITERS:

English

SEARCH STRATEGY:

su= “antidepressant drugs” OR de= “antidepressant drugs” OR kw: fluoxetine OR kw: sertraline OR kw: paroxetine OR kw: citalopram OR kw: fluvoxamine OR kw: bupropion OR kw: nefazodone OR kw: mirtazapine OR kw: venlafaxine OR kw: escitalopram OR kw: duloxetine OR kw: trazodone

AND

de: depressi* OR su: depressi* OR kw: dysthymi*

AND

kw: longitudinal OR kw: cohort* OR (kw: case and kw: control) OR kw: case-control OR kw: comparative OR kw: observational

NOT

kw: random* OR kw: single-blind* OR (kw: single AND kw: blind*) OR kw: double-blind* OR (kw: double AND kw: blind*)

TOTAL NUMBER OF ITEMS RETRIEVED: 62

SEARCH #4A – DRUG INTERACTIONS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

OTHER LIMITERS:

English

Human

Adult (19 years+)

SEARCH STRATEGY:

“antidepressive agents, second-generation”[mh] OR “fluoxetine”[mh] OR “sertraline”[mh] OR “paroxetine”[mh] OR “citalopram”[mh] OR “fluvoxamine”[mh] OR “bupropion”[mh] OR “nefazodone”[nm] OR “mirtazapine”[nm] OR “venlafaxine”[nm] OR “escitalopram”[tw] OR “duloxetine”[nm] OR “trazodone”[mh] OR OR antidepressive agents, second-generation OR fluoxetine[mh] OR sertraline[mh] OR paroxetine[mh] OR citalopram[mh] OR fluvoxamine[mh] OR bupropion[mh] OR nefazodone[nm] OR mirtazapine[nm] OR venlafaxine[nm] OR escitalopram OR duloxetine[nm] OR trazodone[mh]

AND

“depressive disorder”[mh] OR “depressive disorder, major”[mh] OR “depression, involutional”[tw] OR “dysthymic disorder”[mh] OR “subsyndronal depressive disorder”[tw] OR depressive disorder[mh] OR depressive disorder, major[mh] OR depression, involutional[tw] OR dysthymic disorder[mh] OR subsyndronal depressive disorder[tw]

AND

drug interactions[mh]

NOT

“randomized controlled trial”[pt] OR “randomized controlled trials”[mh] OR “single-blind method”[mh] OR “double-blind method”[mh] OR “random allocation”[mh] OR randomized controlled trial[pt] OR

randomized controlled trials[mh] OR single-blind method[mh] OR double-blind method[mh] OR random allocation[mh]

TOTAL NUMBER OF ITEMS RETRIEVED: 14

SEARCH #4B – DRUG INTERACTIONS:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

OTHER LIMITERS:

English

SEARCH STRATEGY:

su= “antidepressant drugs” OR de= “antidepressant drugs” OR kw: fluoxetine OR kw: sertraline OR kw: paroxetine OR kw: citalopram OR kw: fluvoxamine OR kw: bupropion OR kw: nefazodone OR kw: mirtazapine OR kw: venlafaxine OR kw: escitalopram OR kw: duloxetine OR kw: trazodone

AND

de: depressi* OR su: depressi* OR kw: dysthymi*

AND

kw: interact*

NOT

kw: random* OR kw: single-blind* OR (kw: single AND kw: blind*) OR kw: double-blind* OR (kw: double AND kw: blind*)

TOTAL NUMBER OF ITEMS RETRIEVED: 71

SEARCH #5 – RECURRENCE:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

OTHER LIMITERS:

English

Human

Adult (19 years+)

SEARCH STRATEGY:

“antidepressive agents, second-generation”[mh] OR “fluoxetine”[mh] OR “sertraline”[mh] OR “paroxetine”[mh] OR “citalopram”[mh] OR “fluvoxamine”[mh OR “bupropion”[mh] OR “nefazodone”[nm] OR “mirtazapine”[nm] OR “venlafaxine”[nm] OR “escitalopram”[tw] OR “duloxetine”[nm] OR “trazodone”[mh] OR antidepressive agents, second-generation OR fluoxetine[mh] OR sertraline[mh] OR paroxetine[mh] OR citalopram[mh] OR fluvoxamine[mh] OR bupropion[mh] OR nefazodone[nm] OR mirtazapine[nm] OR venlafaxine[nm] OR escitalopram OR duloxetine[nm] OR trazodone[mh]

AND

“depressive disorder”[mh] OR “depressive disorder, major”[mh] OR “depression, involutional”[tw] OR “dysthymic disorder”[mh] OR “subsyndronal depressive disorder”[tw] OR depressive disorder[mh] OR depressive disorder, major[mh] OR depression, involutional[tw] OR dysthymic disorder[mh] OR subsyndronal depressive disorder[tw]

AND

“recurrence”[mh] OR remission[tw] OR relapse[tw] OR recurrence[mh] OR remission[tw] OR relapse[tw]

NOT

“randomized controlled trial”[pt] OR “randomized controlled trials”[mh] OR “single-blind method”[mh] OR “double-blind method”[mh] OR “random allocation”[mh] OR randomized controlled trial[pt] OR randomized controlled trials[mh] OR single-blind method[mh] OR double-blind method[mh] OR random allocation[mh]

TOTAL NUMBER OF ITEMS RETRIEVED: 52

SEARCH #5B – RECURRENCE:

DATABASES SEARCHED & TIME PERIOD COVERED:

PsycINFO –2006–2008

OTHER LIMITERS:

English

SEARCH STRATEGY:

su= “antidepressant drugs” OR de= “antidepressant drugs” OR kw: fluoxetine OR kw: sertraline OR kw: paroxetine OR kw: citalopram OR kw: fluvoxamine OR kw: bupropion OR kw: nefazodone OR kw: mirtazapine OR kw: venlafaxine OR kw: escitalopram OR kw: duloxetine OR kw: trazodone

AND

de: depressi* OR su: depressi* OR kw: dysthymi*

AND

kw: recur* OR kw: remission* OR kw: relaps*

NOT

kw: random* OR kw: single-blind* OR (kw: single AND kw: blind*) OR kw: double-blind* OR (kw: double AND kw: blind*)

TOTAL NUMBER OF ITEMS RETRIEVED: 196

SEARCH #6 – SSRI’s

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed – 2006–2008

OTHER LIMITERS:

Humans

English

Adult (19+ yrs of age)

SEARCH STRATEGY:

serotonin uptake inhibitors

AND

“depressive disorder”[mh] OR “depressive disorder, major”[mh] OR “depression, involutional”[tw] OR “dysthymic disorder”[mh] OR “subsyndronal depressive disorder”[tw] OR depressive disorder[mh] OR depressive disorder, major[mh] OR depression, involutional[tw] OR dysthymic disorder[mh] OR subsyndronal depressive disorder[tw]

AND

“recurrence”[mh] OR remission[tw] OR relapse[tw] OR recurrence[mh] OR remission[tw] OR relapse[tw]

NOT

“randomized controlled trial”[pt] OR “randomized controlled trials”[mh] OR “single-blind method”[mh] OR “double-blind method”[mh] OR “random allocation”[mh] OR randomized controlled trials as topic OR randomized controlled trial[pt] OR randomized controlled trials as topic[mh] OR single-blind method[mh] OR double-blind method[mh] OR random allocation[mh]

TOTAL NUMBER OF ITEMS RETRIEVED: 65

SEARCH #7A – LIMITED SEARCH STRATEGY:

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2000–2008

OTHER LIMITERS:

Publication types:

Editorial

Review

Comment

SEARCH STRATEGY:

“antidepressive agents, second-generation”[mh] OR “fluoxetine”[mh] OR “sertraline”[mh] OR “paroxetine”[mh] OR “citalopram”[mh] OR “fluvoxamine”[mh OR “bupropion”[mh] OR “nefazodone”[nm] OR “mirtazapine”[nm] OR “venlafaxine”[nm] OR “escitalopram”[tw] OR “duloxetine”[nm] OR “trazodone”[mh] OR antidepressive agents, second-generation OR fluoxetine[mh] OR sertraline[mh] OR paroxetine[mh] OR citalopram[mh] OR fluvoxamine[mh] OR bupropion[mh] OR nefazodone[nm] OR mirtazapine[nm] OR venlafaxine[nm] OR escitalopram OR duloxetine[nm] OR trazodone[mh]

AND

“annals of internal medicine” OR “british medical journal” OR “jama” OR “lancet” OR “new england journal of medicine” OR “archives of general psychiatry” OR “american journal of psychiatry”

TOTAL NUMBER OF ITEMS RETRIEVED: 15

SEARCH #7B – LIMITED SEARCH STRATEGY (Revised):

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed – 2006–2008

OTHER LIMITERS:

Publication types:

Editorial

Letter

Comment

SEARCH STRATEGY:

“antidepressive agents, second-generation”[mh] OR “fluoxetine”[mh] OR “sertraline”[mh] OR “paroxetine”[mh] OR “citalopram”[mh] OR “fluvoxamine”[mh OR “bupropion”[mh] OR “nefazodone”[nm] OR “mirtazapine”[nm] OR “venlafaxine”[nm] OR “escitalopram”[tw] OR “duloxetine”[nm] OR “trazodone”[mh] OR antidepressive agents, second-generation OR fluoxetine[mh] OR sertraline[mh] OR paroxetine[mh] OR citalopram[mh] OR fluvoxamine[mh] OR bupropion[mh] OR nefazodone[nm] OR mirtazapine[nm] OR venlafaxine[nm] OR escitalopram OR duloxetine[nm] OR trazodone[mh]

AND

“annals of internal medicine” OR “british medical journal” OR “jama” OR “lancet” OR “new england journal of medicine” OR annals of internal medicine OR british medical journal OR jama OR lancet OR new england journal of medicine OR “archives of general psychiatry” OR “american journal of psychiatry” OR archives of general psychiatry OR american journal of psychiatry

TOTAL NUMBER OF ITEMS RETRIEVED: 49

SEARCH #7C – LIMITED SEARCH STRATEGY (Revised to include all publication types):

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed – 2006–2008

SEARCH STRATEGY:

“antidepressive agents, second-generation”[mh] OR “fluoxetine”[mh] OR “sertraline”[mh] OR “paroxetine”[mh] OR “citalopram”[mh] OR “fluvoxamine”[mh OR “bupropion”[mh] OR “nefazodone”[nm] OR “mirtazapine”[nm] OR “venlafaxine”[nm] OR “escitalopram”[tw] OR “duloxetine”[nm] OR “trazodone”[mh] OR antidepressive agents, second-generation OR fluoxetine[mh] OR sertraline[mh] OR paroxetine[mh] OR citalopram[mh] OR fluvoxamine[mh] OR bupropion[mh] OR nefazodone[nm] OR mirtazapine[nm] OR venlafaxine[nm] OR escitalopram OR duloxetine[nm] OR trazodone[mh]

AND

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] OR “Arch Gen Psychiatry”[Journal:__jrid744] OR american journal of psychiatry[ta]

TOTAL NUMBER OF ITEMS RETRIEVED: 135

SEARCH #7D – LIMITED SEARCH STRATEGY:

DATABASES SEARCHED & TIME PERIOD COVERED:

PscyINFO –2006–2008

OTHER LIMITERS:

English

Publication types:

Editorial

Letter

Comment

SEARCH STRATEGY:

su= “antidepressant drugs” OR de= “antidepressant drugs” OR kw: fluoxetine OR kw: sertraline OR kw: paroxetine OR kw: citalopram OR kw: fluvoxamine OR kw: bupropion OR kw: nefazodone OR kw: mirtazapine OR kw: venlafaxine OR kw: escitalopram OR kw: duloxetine OR kw: trazodone

AND

de: depressi* or su: depressi* or kw: dysthymi*

AND

(kw: annals w1 internal w1 medicine) OR (kw: british w medical w journal) OR kw: jama OR kw: lancet OR (kw: new w england w journal w1 medicine) or (kw: archives w1 general w1 psychiatry) OR (kw: american w journal w1 psychiatry)

TOTAL NUMBER OF ITEMS RETRIEVED: 143

SEARCH #7E – LIMITED SEARCH STRATEGY – Revised to increase date coverage:

DATABASES SEARCHED & TIME PERIOD COVERED:

PscyINFO – 2000–2008

OTHER LIMITERS:

English

SEARCH STRATEGY:

su= “antidepressant drugs” OR de= “antidepressant drugs” OR kw: fluoxetine OR kw: sertraline OR kw: paroxetine OR kw: citalopram OR kw: fluvoxamine OR kw: bupropion OR kw: nefazodone OR kw: mirtazapine OR kw: venlafaxine OR kw: escitalopram OR kw: duloxetine OR kw: trazodone

AND

de: depressi* or su: depressi* or kw: dysthymi*

AND

(kw: annals w1 internal w1 medicine) OR (kw: british w medical w journal) OR kw: jama OR kw: lancet OR (kw: new w england w journal w1 medicine) or (kw: archives w1 general w1 psychiatry) OR (kw: american w journal w1 psychiatry)

TOTAL NUMBER OF ITEMS RETRIEVED: 298

## CER 9 – CABG VERSUS PCI – 2008 UPDATE: SEARCH METHODOLOGY

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

SEARCH STRATEGY:

balloon angioplasty OR (balloon AND dilat* AND coronary) OR (coronary AND atherectom*) OR (balloon AND angioplast*) OR “Angioplasty, Transluminal, Percutaneous Coronary”[Mesh] OR (percutaneous[tiab] AND coronary AND transluminal AND angioplast*) OR ptca[tiab] OR transluminal coronary angioplasty[mh] OR pci[tiab] OR (percutaneous AND coronary AND intervention*[tiab]) OR transluminal coronary angioplasty OR percutaneous coronary intervention OR stents OR stent OR stent[tiab] OR stents[tiab] OR stenting[tiab]

AND

coronary artery bypass OR coronary bypass OR cabg OR coronary artery bypass surgery[mh] OR coronary artery bypass graft

AND

randomized controlled trial* OR randomized controlled trials OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt] OR triple blind* OR triple-blind* OR single blind* OR single-blind* OR double blind* OR double-blind* OR treble blind* OR treble-blind* OR placebo*

AND

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] OR “Am J Cardiol”[Journal:__jrid408] OR “Circulation”[Journal:__jrid2979] OR “J Am Coll Cardiol”[Journal:__jrid4429] OR “Heart”[Journal:__jrid20297]

TOTAL NUMBER OF ITEMS RETRIEVED: 114

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane DARE – No date limit allowed

SEARCH STRATEGY:

(balloon angioplasty OR (balloon and dilat$ and coronary) OR (coronary and atherectom$) OR (balloon and angioplast$) OR Angioplasty, Transluminal, Percutaneous Coronary OR ((percutaneous and coronary and transluminal and angioplast$) OR ptca OR (percutaneous coronary intervention) OR stents OR stent OR stenting).mp. [mp=title, full text, keywords]

AND

(coronary artery bypass or coronary bypass or cabg or coronary artery bypass surgery or coronary artery bypass graft).mp.

TOTAL NUMBER OF ITEMS RETRIEVED: 71

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Database of Systematic Reviews – 2006–2008

SEARCH STRATEGY:

(balloon angioplasty OR (balloon and dilat$ and coronary) OR (coronary and atherectom$) OR (balloon and angioplast$) OR Angioplasty, Transluminal, Percutaneous Coronary OR ((percutaneous and coronary and transluminal and angioplast$) OR ptca OR (percutaneous coronary intervention) OR stents OR stent OR stenting).mp. [mp=title, full text, keywords]

AND

(coronary artery bypass or coronary bypass or cabg or coronary artery bypass surgery or coronary artery bypass graft).mp.

TOTAL NUMBER OF ITEMS RETRIEVED: 17

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Central (Controlled Trials Register) – 2006–2008

SEARCH STRATEGY:

(balloon angioplasty OR (balloon and dilat$ and coronary) OR (coronary and atherectom$) OR (balloon and angioplast$) OR Angioplasty, Transluminal, Percutaneous Coronary OR ((percutaneous and coronary and transluminal and angioplast$) OR ptca OR (percutaneous coronary intervention) OR stents OR stent OR stenting).mp. [mp=title, full text, keywords]

AND

(coronary artery bypass or coronary bypass or cabg or coronary artery bypass surgery or coronary artery bypass graft).mp.

TOTAL NUMBER OF ITEMS RETRIEVED: 83

## CER 10 – ANGIOTENSIN-CONVERTING ENZYME INHIBITORS – 2008 UPDATE: SEARCH METHODOLOGY

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

SEARCH STRATEGY:

“Angiotensin-Converting Enzyme Inhibitors”[Mesh] OR “Angiotensin II Type 1 Receptor Blockers”[Mesh] OR losartan OR valsartan OR telmisartan OR eprosartan OR candesartan OR irbesartan OR olmesartan OR losartan[mh] OR cozaar OR micardis OR atacand OR teveten OR avapro OR benicar OR diovan OR quinapril OR perindopril OR ramipril OR captopril OR enalapril OR benazepril OR trandolapril OR fosinopril OR moexipril OR enalaprilat OR cilazapril OR lisinopril OR angiotensin converting OR (ace AND inhibitor*) OR (angiotensin AND block*)

AND

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] OR “Am J Cardiol”[Journal:__jrid408] OR “Circulation”[Journal:__jrid2979] OR “J Am Coll Cardiol”[Journal:__jrid4429] OR “Heart”[Journal:__jrid20297] OR “Hypertension”[Journal:__jrid4217] OR “Stroke”[Journal:__jrid7613]

AND

randomized controlled trial* randomized controlled trials[mh] OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt])

TOTAL NUMBER OF ITEMS RETRIEVED: 290

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane DARE – No date limit allowed

SEARCH STRATEGY:

Angiotensin-Converting Enzyme Inhibitors OR Angiotensin II Type 1 Receptor Blockers OR losartan OR valsartan OR telmisartan OR eprosartan OR candesartan OR irbesartan OR olmesartan OR cozaar OR micardis OR atacand OR teveten OR avapro OR benicar OR diovan OR quinapril OR perindopril OR ramipril OR captopril OR enalapril OR benazepril OR trandolapril OR fosinopril OR moexipril OR enalaprilat OR cilazapril OR lisinopril {No Related Terms}

AND

hypertension OR hypertensive OR hypertense OR high blood pressure OR lower blood pressure {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 27

TOTAL NUMBER OF RELEVANT ITEMS IDENTIFIED: 1

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Database of Systematic Reviews – 2006–2008

SEARCH STRATEGY:

Angiotensin-Converting Enzyme Inhibitors OR Angiotensin II Type 1 Receptor Blockers OR losartan OR valsartan OR telmisartan OR eprosartan OR candesartan OR irbesartan OR olmesartan OR cozaar OR micardis OR atacand OR teveten OR avapro OR benicar OR diovan OR quinapril OR perindopril OR ramipril OR captopril OR enalapril OR benazepril OR trandolapril OR fosinopril OR moexipril OR enalaprilat OR cilazapril OR lisinopril {No Related Terms}

AND

hypertension OR hypertensive OR hypertense OR high blood pressure OR lower blood pressure {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 69

TOTAL NUMBER OF RELEVANT ITEMS IDENTIFIED: 1

DATABASES SEARCHED & TIME PERIOD COVERED:

Cochrane Central (Controlled Trials Register) – 2006–2008

SEARCH STRATEGY:

Angiotensin-Converting Enzyme Inhibitors OR Angiotensin II Type 1 Receptor Blockers OR losartan OR valsartan OR telmisartan OR eprosartan OR candesartan OR irbesartan OR olmesartan OR cozaar OR micardis OR atacand OR teveten OR avapro OR benicar OR diovan OR quinapril OR perindopril OR ramipril OR captopril OR enalapril OR benazepril OR trandolapril OR fosinopril OR moexipril OR enalaprilat OR cilazapril OR lisinopril {No Related Terms}

AND

hypertension OR hypertensive OR hypertense OR high blood pressure OR lower blood pressure {No Related Terms}

TOTAL NUMBER OF ITEMS RETRIEVED: 27

## CER 11 – RHEUMATOID / PSORIATIC ARTHRITIS – 2008 UPDATE: SEARCH METHODOLOGY

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2006–2008

LIMITERS:

English

Human

SEARCH STRATEGY:

psoriatic arthritis[MeSH] OR “psoriatic arthritis”[all fields] OR rheumatoid arthritis[MeSH] OR “rheumatoid arthritis”[all fields]

AND

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] OR “Br J Rheumatol”[Journal:__jrid1901] OR “J Rheumatol”[Journal:__jrid5243] OR “J Rheumatol Suppl”[Journal:__jrid5244] OR “Arthritis Rheum”[Journal:__jrid881]

AND

randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt]

TOTAL NUMBER OF ITEMS RETRIEVED: 340

## CER 12 – OSTEOPOROSIS/LOW BONE DENSITY – 2008 UPDATE: SEARCH METHODOLOGY

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2005–2008

LIMITERS:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density OR fractures, bones

AND

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] 19:15:50 367459 OR “Bone”[Journal:__jrid1710] OR “J Bone Miner Res”[Journal:__jrid104]) OR “Osteoporos Int”[Journal:__jrid2061]) OR “Endocr Rev”[Journal:__jrid3558]

AND

randomized controlled trial* OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt])

TOTAL NUMBER OF ITEMS RETRIEVED: 576

## CER 13 – PROSTATE CANCER – 2008 UPDATE: SEARCH METHODOLOGY

DATABASES SEARCHED & TIME PERIOD COVERED:

PubMed –2004–2008

SEARCH STRATEGY:

prostatic neoplasms OR prostate cancer

AND

randomized controlled trial* OR randomized controlled trials OR rct* OR random allocation OR randomi* OR double blind OR double-blind OR single blind OR single-blind OR letter* OR editorial* OR comment* OR letter[pt] OR editorial[pt] OR comment[pt] OR randomized controlled trial[pt] OR triple blind* OR triple-blind* OR single blind* OR single-blind* OR double blind* OR double-blind* OR treble blind* OR treble-blind* OR placebo*

AND

“JAMA”[Journal:__jrid5346] OR “N Engl J Med”[Journal:__jrid5985] OR “Lancet”[Journal:__jrid5470] OR “Br Med J”[Journal:__jrid1912] OR “Br Med J (Clin Res Ed)”[Journal:__jrid1913] OR “BMJ”[Journal:__jrid2274] OR “Ann Intern Med”[Journal:__jrid596] OR “J Urol”[Journal:__jrid5331] OR “Cancer”[Journal:__jrid2771] OR “J Clin Oncol”[Journal:__jrid5023]

NOT

animals NOT humans

TOTAL NUMBER OF ITEMS RETRIEVED: 540