# Results and Conclusions

For each of the CERs reviewed, this Attachment provides the findings of our searches of the literature and FDA MedWatch Database and expert assessments, along with our overall recommendation regarding updating and the conclusion(s) on which each recommendation is based.

## CER 1. Comparative Effectiveness of Management for Gastroesophageal Reflux Disease

For this assessment, a limited literature search was conducted for the years 2005–2008. This search included the five generalist journals listed in the Methods and five specialty journals (as recommended by the subject matter experts): Gastroenterology; American Journal of Gastroenterology; Clinical Gastroenterology and Hepatology; Gut; and Alimentary Pharmacology and Therapeutics. The search identified 296 titles, of which 124 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, non-systematic reviews, or did not include topics of relevance. Of those selected for further review, 35 were abstracted into an evidence table (Attachment I). The remaining articles were rejected because they had already been included in the earlier report or did not include a comparison of interest.

We consulted the project lead, four members of the TEP, and 6 additional experts for their assessments. Of these 11 individuals, 6 responded.

Table 2.1 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.1 CER 1. Comparative Effectiveness of Management for Gastroesophageal Reflux Disease (GERD): Are the conclusions still valid?

Conclusions From CER Executive Summary | RAND Literature Search | FDA/Health Canada | Expert Opinion | Conclusion from SCEPC
Conclusions From CER Executive Summary | RAND Literature Search | FDA/Health Canada | EPC Investigator, 5 Other Experts | Conclusion from SCEPC
Key Question 1: What is the evidence of the comparative effectiveness of medical, surgical, and endoscopic treatments for improving objective and subjective outcomes in patients with chronic GERD?
Medical therapy with PPIs and surgery (fundoplication) appeared to be similarly effective for improving symptoms and decreasing esophageal acid exposure. 10 percent to 65 percent of surgical patients still require medications. The limited data available did not support a significant benefit of fundoplication compared with medical therapy for preventing Barrett's esophagus or esophageal adenocarcinoma. | A multicenter randomized controlled trial (RCT) found laparoscopic antireflux surgery (LARS) vs. esomeprazole were similarly effective and well-tolerated over 3 years (Lundell, 2008). | FDA 6/30/2008 approved ACIPHEX (RABEPRAZOLE SODIUM) in short-term treatment of symptomatic GERD in adolescent patients 12 years of age and above. | All experts agreed this conclusion is still valid. One expert notes that very little is new (see Spechler, 2001). | Conclusion is still valid and this portion of the CER does not need updating.
Of the three nonrandomized studies that compared an endoscopic procedure with laparoscopic fundoplication in patients with GERD documented by pH or endoscopy, the longest follow-up was 8 months, and all three studies had significant bias that may invalidate the results. Two studies reported that more patients treated with laparoscopic fundoplication were satisfied with their results compared with those who had EndoCinchTM. One of these studies and a study of Stretta® also found less need for PPIs in patients who had fundoplication. | A nonrandomized prospective study of 51 patients with persistent GERD comparing transesophageal endoscopic plication (TEP) with laparoscopic Nissen fundoplication (LNF) found that both techniques improved symptom score, acid regurgitation, quality of life, and reduced requirement for PPIs. Control of heartburn and acid reflux was better for LNF. TEP, like LNF, had comparable safety and efficacy (Mahmood, 2006). A RCT comparing endoluminal gastroplasty (EndoCinch) with polymer injection (Enteryx) over 6 months demonstrated equal effectiveness in reducing PPI dosages and improving symptoms of patients. (Domagk, 2006) | Not applicable. | Experts agreed this conclusion is no longer applicable as these endoscopic techniques are no longer in use. One expert noted that the overall appeal for these interventions has dropped off significantly, so there has been very little in the way of important new studies on endotherapies for GERD. One expert said the conclusion was no longer relevant since endoscopic therapy for GERD is not actively being used. Stretta is off the market. | Original conclusion should probably be deleted as the endoscopic procedure is no longer in use.
There was no head-to-head comparison of medical treatments with endoscopic treatments. | No new evidence. | Not applicable. | Two experts agreed the conclusion is no longer applicable as these endoscopic techniques are no longer in use. One expert noted there is nothing new. | Original conclusion should probably be deleted as the endoscopic procedure is no longer in use.
PPIs were superior to H2RAs (histamine 2 receptor inhibitors) in resolution of GERD symptoms at 4 weeks and healing of esophagitis at 8 weeks. There was no difference between omeprazole, lansoprazole, pantoprazole, and rabeprazole for relief of symptoms at 8 weeks. No significant difference was found in the comparisons of esomeprazole 40 mg with lansoprazole 30 mg or pantoprazole 40 mg for relief of symptoms at 4 weeks. Similarly, there was no difference in the comparison of esomeprazole 20 mg with omeprazole 20 mg in relief of symptoms at 4 weeks. | A meta-analysis of 10 studies compared rates of endoscopic healing, symptom relief, and adverse events of esomeprazole versus alternative PPIs in treatment of erosive esophagitis. Esomeprazole demonstrated a statistically significant improvement, but only modest clinical benefit in improved healing of erosive esophagitis at 8-weeks. There is no evidence of what is believed to be “clinically meaningful improvement in symptom relief” between PPIs (Gralnek, 2006). A systematic review of RCTs in patients with reflux esophagitis demonstrates esomeprazole consistently has higher healing rates when compared with standard dose PPIs at 4 and 8 weeks (Edwards, 2006). A new RCT of patients with erosive esophagitis comparing PPI maintenance therapy demonstrates esomeprazole 20 mg qday is more effective than lansoprazole 15 mg qday in maintaining endoscopic/symptomatic mission in patients with healed erosive esophagitis (Devault, 2006). A new of GERD patients demonstrates famotidine 20 mg BID and omeprazole 20 mg qday were both effective in improving GERD symptoms, particularly non- erosive GERD disease over a period of 8 weeks (Wada, 2006). A new RCT of patients with healed erosive esophagitis demonstrates esomeprazole 20 mg is superior to pantoprazole 20 mg for maintenance therapy following healed erosive esophagitis and relief of GERD symptoms at 6 months (Lubenz, 2005). A new RCT of patients with NERD found that, in patients who are H pylori negative, omeprazole is more effective than famotidine for control of GERD symptoms, but in H. pylori positive symptoms, similar efficacy was observed (Fujiwara, 2005). | FDA 4/27/2007 revised the Precautions section of PRILOSEC (OMEPRAZOLE) “Concomitant administration of omeprazole and voriconazole (a combined inhibitor of CYP2C19 and CYP3A4) resulted in more than doubling of the omeprazole exposure. Dose adjustment of omeprazole is not normally required. However, in patients with Zollinger-Ellison's syndrome, who may require higher doses up to 240 mg/day, dose adjustment may be considered.” FDA 6/30/2008 approved ACIPHEX (RABEPRAZOLE SODIUM) in short-term treatment of symptomatic GERD in adolescent patients 12 years of age and above. | One expert noted a meta-analysis revealed a benefit for esomeprazole for healing rates and symptom response rates (Gralnek, 2006). Other experts stated the conclusion was still valid. | Conclusion is probably out of date and this portion of the CER may need updating based on a wealth of new data.
For maintenance medical treatment of 6 months to 1 year, PPIs taken at a standard dose were more effective than those taken at a lower dose. | No new evidence. | FDA 4/21/2008 revised warning section of PREVACID (Lansoprazole) for inclusion of Clostridium difficile associated diarrhea. “Physicians use combination therapy with PREVACID plus amoxicillin and clarithromycin for the treatment of patients with H. pylori infection and duodenal ulcer disease (active or five-year history of duodenal ulcer) to eradicate H. pylori.” | Experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Laparoscopic fundoplication was as effective as open fundoplication for relieving heartburn and regurgitation, improving quality of life, and decreasing use of antisecretory medications. Almost 90 percent of patients who were followed for 5 or more years in both surgical arms reported improvement in symptoms. | No new evidence. | Not applicable. | Experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Compared to sham, StrettaTM was more effective in improving symptoms of reflux and improving quality of life at 6 months and was associated with a decrease in the need for antisecretory medications. Improvement of esophageal pH exposure compared with sham could not be demonstrated for StrettaTM. | Compared to sham, endoscopic gastroplication using Endocinch device reduced acid-inhibitory drug use, improved GERD symptoms, and improved quality of life (Schwartz, 2007). | Not applicable. | Experts agreed the conclusion is no longer applicable as these endoscopic techniques are no longer in use. One expert said this was also true in the Endocinch sham trial although this study was not as rigorous as the Stretta study (Schwartz, 2007). One expert noted that Stretta is off the market because of adverse events. | Original conclusion should probably be deleted as the endoscopic procedure is no longer in use.
Key Question 2: Is there evidence that effectiveness of medical, surgical, and endoscopic treatments varies for specific patient subgroups?
Patients on maintenance antireflux medications may have higher rates of esophagitis if they have any of the following factors: increased severity of esophagitis at baseline (pretreatment), younger age, and moderate to severe regurgitation. | No new evidence. | No new information. | Experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There is no substantial evidence to support a difference in surgical outcome based on age, preoperative presence or severity of esophagitis, lower esophageal sphincter incompetence, or esophageal body hypomotility. Patients treated surgically who have a history of psychiatric disorders may have worse symptom and satisfaction outcomes than those without a significant psychiatric history. | No new evidence. | No new information. | Experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 3: What are the short- and long- term adverse effects associated with specific medical, surgical, and endoscopic therapies for GERD?
Higher adverse event rates were described for PPIs than for H2RAs or placebo. The most commonly cited events for PPIs and H2RAs were headache, diarrhea, and abdominal pain. | No new evidence. | FDA 4/21/2008 revised warning section of PREVACID (Lansoprazole) for inclusion of Clostridium difficile associated diarrhea. “Physicians use combination therapy with PREVACID plus amoxicillin and clarithromycin for the treatment of patients with H. pylori infection and duodenal ulcer disease (active or five-year history of duodenal ulcer) to eradicate H. pylori” FDA 4/27/2007 revised the Precautions section of PRILOSEC (OMEPRAZOLE) “Concomitant administration of omeprazole and voriconazole (a combined inhibitor of CYP2C19 and CYP3A4) resulted in more than doubling of the omeprazole exposure. Dose adjustment of omeprazole is not normally required. However, in patients with Zollinger-Ellison syndrome, who may require higher doses up to 240 mg/day, dose adjustment may be considered.” | Experts agreed the conclusion is still valid. One expert notes it is important to capture the new data regarding other complications of PPIs (albeit rare complications), like Clostridium difficile colitis, pneumonia, osteoporosis, interstitial cystitis, and small intestinal bacterial overgrowth. It might also be important to emphasize that the side effect profile varies by PPI type. For example, headache is more common with Esomeprazole, diarrhea with lansoprazole. | Conclusion is possibly out of date and this portion of the CER may need updating based on expert opinion about newly recognized adverse events.
The most commonly reported complications occurring intraoperatively or within 30 days after open fundoplication were the need for splenectomy, dysphagia, inability to belch, and inability to vomit. The most commonly reported complications for laparoscopic procedures were gastric or esophageal injury or perforation, splenic injury or splenectomy, pneumothorax, bleeding, pneumonia, fever, wound infections, bloating, and dysphagia. Major complications were generally reported at very low rates. | No new evidence. | No new information. | Experts agree still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Frequently reported complications for endoscopic treatments (intraoperatively or within 30 days after the procedure) included chest or retrosternal pain, gastrointestinal injury, bleeding, and short-term dysphagia. The frequency and types of complications varied with the different procedures. Serious complications, including fatalities, have also been described. | No new evidence. | No new information. | One expert noted that Enteryx is now off the market because of severe AEs. The specific AE profiles depend very much on which endotherapy is being used. One expert said that esophageal perforations have been reported. Stretta is off the market | Original conclusion should probably be deleted as the endoscopic procedure is no longer in use.
Additional information: One expert suggested: One might considering summarizing the literature comparing the effectiveness of continuous with on-demand proton pump inhibitor therapy for patients with GERD Therefore, RAND researched this topic: Timing of treatment-“On-demand” vs. “intermittent” vs. “continuous” therapy: a) A systematic review of 17 studies found on-demand PPI is effective in long-term management of patients with NERD or mild and uninvestigated forms of GERD, but not in patients with severe erosive esophagitis. These studies include on-demand PPI vs. placebo and continuous PPI. (Pace, 2007) b) A systematic review of the efficacy of intermittent and on-demand therapy with H2As and PPIs in patients with erosive esophagitis or symptomatic heartburn found, regarding intermittent therapy, neither PPIs nor H2As were effective in maintaining control of esophagitis patients. In regards to on-demand therapy, PPIs may work in a proportion of non-erosive GERD patients (Zachy, 2005). c) A RCT of patients with erosive reflux esophagitis found that once daily esomeprazole 20 mg was better than “on-demand” for maintaining healed erosive esophagitis at 6 months (Sjostedt, 2005). d) A RCT of patients with NERD or low grade esophagitis demonstrates a slightly higher rate of symptom relief at 6 months with the continuous rabeprazole group versus the on-demand group. For overall quality of life, there was not difference between the groups. Daily consumption was lower for the on-demand treatment group (Bour, 2005). e) A RCT of GERD patients demonstrates that at 6 months, on-demand treatment with lansoprazole in symptomatic patients after short-term, continuous treatment is more effective than placebo in improving symptoms (Bigard, 2005). Laryngeal/pharyngeal symptoms attributed to GERD. Caveat: the cause and effect relationship of GERD and laryngophayngeal reflux remains unclear: a) Meta-analysis of 5 studies using high-dose PPIs for treatment of laryngeal or pharyngeal symptoms was no more effective than placebo in provident symptomatic improvement or resolution of laryngo-pharyngeal symptoms (Gatta, 2007). b) A RCT of 39 patients with laryngopharyngeal reflux treated with pantoprazole vs. placebo found no difference in symptom improvement between the two groups (Wo, 2006). c) Systematic review and meta-analysis of RCTs of patients with chronic cough associated with GERD demonstrated use of PPI for treatment has some effect in some adults, but is less universal than suggested in consensus guidelines on chronic cough (Chang, 2006). Acupuncture vs. doubling PPI dose: A RCT of 30 patients with refractory heartburn compared doubling PPI dose vs. acupuncture twice weekly found adding acupuncture was more effective than doubling PPI dose in controlling GERD symptoms (Dickman, 2007). Double dose or change PPI: A RCT of patients with persistent heartburn symptoms found switching patients to different PPI was as effective as increasing PPI dosage to twice daily for controlling heartburn symptoms (Fass, 2006). Long-term prevention of erosive or ulcerative GERD relapse: A RCT of patients with healed erosive/ulcerative GERD found 5-year maintenance therapy with rabeprazole was effective in preventing relapse of erosive/ulcerative GERD. 20 mg was better than 10 mg. Both was better than placebo (Caos, 2005). New endoscopic techniques: Radiofrequency energy delivery allows reduction or discontinuation of PPI therapy in patients with PPI-dependent symptoms (Coron, 2008). AZD0865, potassium-competitive acid blocker: a) A RCT comparing a potassium-competitive acid blocker (AZD0865) did not provide clinical benefit over esomeprazole in patients with nonerosive reflux disease (Dent, 2008). b) A RCT compared three doses of potassium-competitive acid blocker (AZD0865) (25, 50, 75 mg) with esomeprazole 40 mg. At 4 weeks, healing rates of esophagitis was similar to esomeprazole. No significant difference was found in heartburn control. AZD0865 at 75 mg was demonstrated reversible increases in liver transaminases (Kahrilas, 2007). Nocturnal symptoms: a) A RCT in GERD patients with nocturnal heartburn concludes single-dose rabeprazole 20mg increases intragastric pH more than pantoprazole 40mg qday (Warrington, 2007). b) A randomized controlled trial in GERD patients with nocturnal symptoms, comparing immediate-release omeprazole 40 mg oral suspension, delayed release lansoprazole 30 mg capsules, and delayed-release esomeprazole 30 mg capsules. Omeprazole was superior to lansoprazole and comparable to esomeprazole (Katz, 2007). c) A RCT in erosive esophagitis patients on daily PPI with experience night-time heart burn finds OTC ranitidine 75 mg reduced symptoms vs. placebo on day 3, but not on day 14 (Vakil, 2006). d) A RCT of patients with nocturnal GERD demonstrates immediate-release omeprazole reduced nocturnal gastric acidity better than delayed-release pantoprazole (Castell, 2005). Early response to therapy predicts complete resolution: Pooled analysis from three multicenter, double-blind trials of patients receiving PPI found that heartburn resolution during 1^st^ week of PPI therapy is the best predictor of treatment success at week 4 (Talley, 2006). Rebound acid hypersecretion: A systematic review of 8 studies demonstrates no strong evidence for clinically relevant increased acid production after cessation of PPI therapy. Only 1 study included patients with reflux esophagitis, and the remaining 7 studies enrolled healthy volunteers (Gatta, 2007). Risk of bacterial gastroenteritis: A case control study of patients with acute bacterial gastroenteritis (GE) compared with a control group without acute bacterial GE found current PPI use was associated with increased risk of bacterial GE. H2A use was not associated with increased risk. Caveat is that this is a heterogeneous patient population, including some with GERD (Rodriguez, 2007).

Legend: AE: adverse event (or effect); GE: gastroenteritis; GERD: gastroesophageal reflux disease; H2As: histamine 2 receptor antagonists; LARS: laparoscopic antireflux surgery; LNF: laparoscopic Nissen fundoplication; NERD: non-erosive reflux disease; PPI: proton pump inhibitor; RCT: randomized controlled trial; TEP: trans-esophageal endoscopic plication

### References

Armstrong D, Veldhuyzen van Zanten SJ, Barkun AN, et al. Heartburn-dominant, uninvestigated dyspepsia: a comparison of 'PPI-start' and 'H2-RA-start' management strategies in primary care--the CADET-HR Study. Aliment Pharmacol Ther. May 15. 2005;21(10):1189-1202. [pmid: 15882239].
Arts J, Caenepeel P, Verbeke K, Tack J. Influence of erythromycin on gastric emptying and meal related symptoms in functional dyspepsia with delayed gastric emptying. Gut. Apr. 2005;54(4):455-460. [pmid: 15753526].
Bardhan KD, Achim A, Riddermann T, Pfaffenberger B. A clinical trial comparing pantoprazole and esomeprazole to explore the concept of achieving 'complete remission' in gastro-oesophageal reflux disease. Aliment Pharmacol Ther. Jun 15. 2007;25(12):1461-1469. [pmid: 17539986].
Bigard MA, Genestin E. Treatment of patients with heartburn without endoscopic evaluation: on-demand treatment after effective continuous administration of lansoprazole 15 mg. Aliment Pharmacol Ther. Oct 1. 2005;22(7):635-643. [pmid: 16181303].
Bjornsson E, Abrahamsson H, Simren M, et al. Discontinuation of proton pump inhibitors in patients on long-term therapy: a double-blind, placebo-controlled trial. Aliment Pharmacol Ther. Sep 15. 2006;24(6):945-954. [pmid: 16948806].
Bour B, Staub JL, Chousterman M, et al. Long-term treatment of gastro-oesophageal reflux disease patients with frequent symptomatic relapses using rabeprazole: on-demand treatment compared with continuous treatment. Aliment Pharmacol Ther. Apr 1. 2005;21(7):805-812. [pmid: 15801915].
Broekaert D, Fischler B, Sifrim D, Janssens J, Tack J. Influence of citalopram, a selective serotonin reuptake inhibitor, on oesophageal hypersensitivity: a double-blind, placebo-controlled study. Aliment Pharmacol Ther. Feb 1. 2006;23(3):365-370. [pmid: 16422995].
Calvet X, Ducons J, Bujanda L, Bory F, Montserrat A, Gisbert JP. Seven versus ten days of rabeprazole triple therapy for Helicobacter pylori eradication: a multicenter randomized trial. Am J Gastroenterol. Aug. 2005;100(8):1696-1701. [pmid: 16086704].
Caos A, Breiter J, Perdomo C, Barth J. Long-term prevention of erosive or ulcerative gastro-oesophageal reflux disease relapse with rabeprazole 10 or 20 mg vs. placebo: results of a 5-year study in the United States. Aliment Pharmacol Ther. Aug 1. 2005;22(3):193-202. [pmid: 16091056].
Castell D, Bagin R, Goldlust B, Major J, Hepburn B. Comparison of the effects of immediate-release omeprazole powder for oral suspension and pantoprazole delayed-release tablets on nocturnal acid breakthrough in patients with symptomatic gastro-oesophageal reflux disease. Aliment Pharmacol Ther. Jun 15. 2005;21(12):1467-1474. [pmid: 15948814].
Chang AB, Lasserson TJ, Kiljander TO, Connor FL, Gaffney JT, Garske LA. Systematic review and meta-analysis of randomised controlled trials of gastro-oesophageal reflux interventions for chronic cough associated with gastro-oesophageal reflux. BMJ. Jan 7. 2006;332(7532):11-17. [pmid: 16330475].
Choung RS, Ferguson DD, Murray JA, et al. A novel partial 5HT3 agonist DDP733 after a standard refluxogenic meal reduces reflux events: a randomized, double-blind, placebo-controlled pharmacodynamic study. Aliment Pharmacol Ther. Mar 1. 2008;27(5):404-411. [pmid: 18081732].
Coron E, Sebille V, Cadiot G, et al. Clinical trial: radiofrequency energy delivery in PPI-dependent GERD patients. Aliment Pharmacol Ther. Jul. 1. 2008.
Cremonini F, Wise J, Moayyedi P, Talley NJ. Diagnostic and therapeutic use of proton pump inhibitors in non-cardiac chest pain: a metaanalysis. Am J Gastroenterol. Jun. 2005;100(6):1226-1232. [pmid: 15929749].
De Jonge PJ, Siersema PD, Van Breda SG, et al. Proton pump inhibitor therapy in gastro-oesophageal reflux disease decreases the oesophageal immune response but does not reduce the formation of DNA adducts. Aliment Pharmacol Ther. Jul. 2008;28(1):127-136. [pmid: 18384663].
Delaney BC, Qume M, Moayyedi P, et al. Helicobacter pylori test and treat versus proton pump inhibitor in initial management of dyspepsia in primary care: multicentre randomised controlled trial (MRC-CUBE trial). BMJ. Mar 22. 2008;336(7645):651-654. [pmid: 18310262].
Dent J, Kahrilas PJ, Hatlebakk J, et al. A randomized, comparative trial of a potassium-competitive acid blocker (AZD0865) and esomeprazole for the treatment of patients with nonerosive reflux disease. Am J Gastroenterol. Jan. 2008;103(1):20-26. [pmid: 18184117].
Devault KR, Johanson JF, Johnson DA, Liu S, Sostek MB. Maintenance of healed erosive esophagitis: a randomized six-month comparison of esomeprazole twenty milligrams with lansoprazole fifteen milligrams. Clin Gastroenterol Hepatol. Jul. 2006;4(7):852-859. [pmid: 16682260].
Deviere J, Costamagna G, Neuhaus H, et al. Nonresorbable copolymer implantation for gastroesophageal reflux disease: a randomized sham-controlled multicenter trial. Gastroenterology. Mar. 2005;128(3):532-540. [pmid: 15765387].
Dickman R, Emmons S, Cui H, et al. The effect of a therapeutic trial of high-dose rabeprazole on symptom response of patients with non-cardiac chest pain: a randomized, double-blind, placebo-controlled, crossover trial. Aliment Pharmacol Ther. Sep 15. 2005;22(6):547-555. [pmid: 16167971].
Dickman R, Schiff E, Holland A, et al. Clinical trial: acupuncture vs. doubling the proton pump inhibitor dose in refractory heartburn. Aliment Pharmacol Ther. Nov 15. 2007;26(10):1333-1344. [pmid: 17875198].
Domagk D, Menzel J, Seidel M, et al. Endoluminal gastroplasty (EndoCinch) versus endoscopic polymer implantation (Enteryx) for treatment of gastroesophageal reflux disease: 6-month results of a prospective, randomized trial. Am J Gastroenterol. Mar. 2006;101(3):422-430. [pmid: 16542275].
Edwards SJ, Lind T, Lundell L. Systematic review: proton pump inhibitors (PPIs) for the healing of reflux oesophagitis - a comparison of esomeprazole with other PPIs. Aliment Pharmacol Ther. Sep 1. 2006;24(5):743-750. [pmid: 16918878].
Fass R, Naliboff BD, Fass SS, et al. The effect of auditory stress on perception of intraesophageal acid in patients with gastroesophageal reflux disease. Gastroenterology. Mar. 2008;134(3):696-705. [pmid: 18206149].
Fass R, Sontag SJ, Traxler B, Sostek M. Treatment of patients with persistent heartburn symptoms: a double-blind, randomized trial. Clin Gastroenterol Hepatol. Jan. 2006;4(1):50-56. [pmid: 16431305].
Fennerty MB, Johanson JF, Hwang C, Sostek M. Efficacy of esomeprazole 40 mg vs. lansoprazole 30 mg for healing moderate to severe erosive oesophagitis. Aliment Pharmacol Ther. Feb 15. 2005;21(4):455-463. [pmid: 15709997].
Ferguson DD, DeVault KR, Krishna M, Loeb DS, Wolfsen HC, Wallace MB. Enhanced magnification-directed biopsies do not increase the detection of intestinal metaplasia in patients with GERD. Am J Gastroenterol. Jul. 2006;101(7):1611-1616. [pmid: 16863568].
Ford AC, Moayyedi P, Jarbol DE, Logan RF, Delaney BC. Meta-analysis: Helicobacter pylori'test and treat' compared with empirical acid suppression for managing dyspepsia. Aliment Pharmacol Ther. Sep 1. 2008;28(5):534-544. [pmid: 18616641].
Fox M, Barr C, Nolan S, Lomer M, Anggiansah A, Wong T. The effects of dietary fat and calorie density on esophageal acid exposure and reflux symptoms. Clin Gastroenterol Hepatol. Apr. 2007;5(4):439-444. [pmid: 17363334].
Fujiwara Y, Higuchi K, Nebiki H, et al. Famotidine vs. omeprazole: a prospective randomized multicentre trial to determine efficacy in non–erosive gastro-oesophageal reflux disease. Aliment Pharmacol Ther. Jun. 2005;21(Suppl 2):10-18. [pmid: 15943841].
Garcia Rodriguez LA, Ruigomez A, Panes J. Use of acid-suppressing drugs and the risk of bacterial gastroenteritis. Clin Gastroenterol Hepatol. Dec. 2007;5(12):1418-1423. [pmid: 18054750].
Garcia-Cano J. Polyflex or ultraflex stents to treat peptic refractory esophageal strictures?. Am J Gastroenterol. Mar. 2008;103(3):803-804. [pmid: 18341504].
Gatta L, Vaira D, Sorrenti G, Zucchini S, Sama C, Vakil N. Meta-analysis: the efficacy of proton pump inhibitors for laryngeal symptoms attributed to gastro-oesophageal reflux disease. Aliment Pharmacol Ther. Feb 15. 2007;25(4):385-392. [pmid: 17269993].
Giannini EG, Zentilin P, Dulbecco P, Vigneri S, Scarlata P, Savarino V. Management strategy for patients with gastroesophageal reflux disease: a comparison between empirical treatment with esomeprazole and endoscopy-oriented treatment. Am J Gastroenterol. Feb. 2008;103(2):267-275. [pmid: 18289194].
Gralnek IM, Dulai GS, Fennerty MB, Spiegel BM. Esomeprazole versus other proton pump inhibitors in erosive esophagitis: a meta-analysis of randomized clinical trials. Clin Gastroenterol Hepatol. Dec. 2006;4(12):1452-1458. [pmid: 17162239].
Grudell AB, Camilleri M, Burton DD, Stephens DA. Effect of a proton pump inhibitor on postprandial gastric volume, emptying and symptoms in healthy human subjects: a pilot study. Aliment Pharmacol Ther. Oct 1. 2006;24(7):1037-1043. [pmid: 16984497].
Haag S, Senf W, Tagay S, et al. Is there a benefit from intensified medical and psychological interventions in patients with functional dyspepsia not responding to conventional therapy?. Aliment Pharmacol Ther. Apr 15. 2007;25(8):973-986. [pmid: 17403002].
Hansen JM, Wildner-Christensen M, Hallas J, Schaffalitzky de Muckadell OB. Effect of a community screening for Helicobacter pylori: a 5-Yr follow-up study. Am J Gastroenterol. May. 2008;103(5):1106-1113. [pmid: 18445098].
Hashash JG, Abdul-Baki H, Azar C, et al. Clinical trial: a randomized controlled cross-over study of flupenthixol + melitracen in functional dyspepsia. Aliment Pharmacol Ther. Jun 1. 2008;27(11):1148-1155. [pmid: 18331614].
Hawkey C, Talley NJ, Yeomans ND, et al. Improvements with esomeprazole in patients with upper gastrointestinal symptoms taking non-steroidal antiinflammatory drugs, including selective COX-2 inhibitors. Am J Gastroenterol. May. 2005;100(5):1028-1036. [pmid: 15842575].
Hawkey CJ, Jones RH, Yeomans ND, et al. Efficacy of esomeprazole for resolution of symptoms of heartburn and acid regurgitation in continuous users of non-steroidal anti-inflammatory drugs. Aliment Pharmacol Ther. Apr 1. 2007;25(7):813-821. [pmid: 17373920].
Hemmink GJ, Bredenoord AJ, Weusten BL, Monkelbaan JF, Timmer R, Smout AJ. Esophageal pH-Impedance Monitoring in Patients With Therapy-Resistant Reflux Symptoms: 'On' or 'Off' Proton Pump Inhibitor. Am J Gastroenterol. Aug. 5. 2008.
Hogan D, Pratha V, Riff D, et al. Oral pantoprazole in the form of granules or tablets are pharmacodynamically equivalent in suppressing acid output in patients with gastro-oesophageal reflux disease and a history of erosive oesophagitis. Aliment Pharmacol Ther. Jul 15. 2007;26(2):249-256. [pmid: 17593070].
Hogan WJ. Clinical trials evaluating endoscopic GERD treatments: is it time for a moratorium on the clinical use of these procedures?. Am J Gastroenterol. Mar. 2006;101(3):437-439. [pmid: 16542277].
Holtmann G, Talley NJ, Liebregts T, Adam B, Parow C. A placebo-controlled trial of itopride in functional dyspepsia. N Engl J Med. Feb 23. 2006;354(8):832-840. [pmid: 16495395].
Hunfeld NG, Geus WP, Kuipers EJ. Systematic review: Rebound acid hypersecretion after therapy with proton pump inhibitors. Aliment Pharmacol Ther. Jan 1. 2007;25(1):39-46. [pmid: 17229219].
Janiak P, Thumshirn M, Menne D, et al. Clinical trial: the effects of adding ranitidine at night to twice daily omeprazole therapy on nocturnal acid breakthrough and acid reflux in patients with systemic sclerosis--a randomized controlled, cross-over trial. Aliment Pharmacol Ther. Nov 1. 2007;26(9):1259-1265. [pmid: 17944740].
Jarbol DE, Kragstrup J, Stovring H, Havelund T, Schaffalitzky de Muckadell OB. Proton pump inhibitor or testing for Helicobacter pylori as the first step for patients presenting with dyspepsia? A cluster-randomized trial. Am J Gastroenterol. Jun. 2006;101(6):1200-1208. [pmid: 16771937].
Jobe BA, Hunter JG, Chang EY, et al. Office-based unsedated small-caliber endoscopy is equivalent to conventional sedated endoscopy in screening and surveillance for Barrett's esophagus: a randomized and blinded comparison. Am J Gastroenterol. Dec. 2006;101(12):2693-2703. [pmid: 17227516].
Johnson DA, Orr WC, Crawley JA, et al. Effect of esomeprazole on nighttime heartburn and sleep quality in patients with GERD: a randomized, placebo-controlled trial. Am J Gastroenterol. Sep. 2005;100(9):1914-1922. [pmid: 16128933].
Johnson DA, Stacy T, Ryan M, et al. A comparison of esomeprazole and lansoprazole for control of intragastric pH in patients with symptoms of gastro-oesophageal reflux disease. Aliment Pharmacol Ther. Jul 15. 2005;22(2):129-134. [pmid: 16011671].
Jones H, Cooper P, Miller V, Brooks N, Whorwell PJ. Treatment of non-cardiac chest pain: a controlled trial of hypnotherapy. Gut. Oct. 2006;55(10):1403-1408. [pmid: 16627548].
Kahrilas PJ, Dent J, Lauritsen K, et al. A randomized, comparative study of three doses of AZD0865 and esomeprazole for healing of reflux esophagitis. Clin Gastroenterol Hepatol. Dec. 2007;5(12):1385-1391. [pmid: 17950677].
Kato M, Watanabe M, Konishi S, et al. Randomized, double-blind, placebo-controlled crossover trial of famotidine in patients with functional dyspepsia. Aliment Pharmacol Ther. Jun. 2005;21(Suppl 2):27-31. [pmid: 15943843].
Katz PO, Ginsberg GG, Hoyle PE, Sostek MB, Monyak JT, Silberg DG. Relationship between intragastric acid control and healing status in the treatment of moderate to severe erosive oesophagitis. Aliment Pharmacol Ther. Mar 1. 2007;25(5):617-628. [pmid: 17305763].
Katz PO, Koch FK, Ballard ED, et al. Comparison of the effects of immediate-release omeprazole oral suspension, delayed-release lansoprazole capsules and delayed-release esomeprazole capsules on nocturnal gastric acidity after bedtime dosing in patients with night-time GERD symptoms. Aliment Pharmacol Ther. Jan 15. 2007;25(2):197-205. [pmid: 17229243].
Kinoshita Y, Hashimoto T, Kawamura A, et al. Effects of famotidine, mosapride and tandospirone for treatment of functional dyspepsia. Aliment Pharmacol Ther. Jun. 2005;21(Suppl 2):37-41. [pmid: 15943845].
Labenz J, Armstrong D, Lauritsen K, et al. Esomeprazole 20 mg vs. pantoprazole 20 mg for maintenance therapy of healed erosive oesophagitis: results from the EXPO study. Aliment Pharmacol Ther. Nov 1. 2005;22(9):803-811. [pmid: 16225489].
Labenz J, Armstrong D, Lauritsen K, et al. A randomized comparative study of esomeprazole 40 mg versus pantoprazole 40 mg for healing erosive oesophagitis: the EXPO study. Aliment Pharmacol Ther. Mar 15. 2005;21(6):739-746. [pmid: 15771760].
Leung WK, Wu JC, Chan FK, et al. Initial treatment with lansoprazole in young dyspeptic patients with negative urea breath test result: a randomized controlled trial with 12-month follow-up. Am J Gastroenterol. Jul. 2007;102(7):1483-1488. [pmid: 17593161].
Lundell L, Attwood S, Ell C, et al. Comparing laparoscopic antireflux surgery with esomeprazole in the management of patients with chronic gastro-oesophageal reflux disease: a 3-year interim analysis of the LOTUS trial. Gut. Sep. 2008;57(9):1207-1213. [pmid: 18469091].
Lundell L, Havu N, Miettinen P, et al. Changes of gastric mucosal architecture during long-term omeprazole therapy: results of a randomized clinical trial. Aliment Pharmacol Ther. Mar 1. 2006;23(5):639-647. [pmid: 16480403].
Mahadeva S, Chia YC, Vinothini A, Mohazmi M, Goh KL. Cost-effectiveness of and satisfaction with a Helicobacter pylori "test and treat" strategy compared with prompt endoscopy in young Asians with dyspepsia. Gut. Sep. 2008;57(9):1214-1220. [pmid: 18441005].
Mahmood Z, Byrne PJ, McMahon BP, et al. Comparison of transesophageal endoscopic plication (TEP) with laparoscopic Nissen fundoplication (LNF) in the treatment of uncomplicated reflux disease. Am J Gastroenterol. Mar. 2006;101(3):431-436. [pmid: 16542276].
Mahon D, Rhodes M. Gastro-oesophageal reflux disease: surgery is an alternative. BMJ. Jan 28. 2006;332(7535):236.
Majewski M, Jaworski T, Sarosiek I, et al. Significant enhancement of esophageal pre-epithelial defense by tegaserod: implications for an esophagoprotective effect. Clin Gastroenterol Hepatol. Apr. 2007;5(4):430-438. [pmid: 17445751].
McQuaid KR, Laine L. Early heartburn relief with proton pump inhibitors: a systematic review and meta-analysis of clinical trials. Clin Gastroenterol Hepatol. Jun. 2005;3(6):553-563. [pmid: 15952097].
Meineche-Schmidt V, Hvenegaard A, Juhl HH. Participation in a clinical trial influences the future management of patients with gastro-oesophageal reflux disease in general practice. Aliment Pharmacol Ther. Oct 1. 2006;24(7):1117-1125. [pmid: 16984506].
Metz DC, Miner PB, Heuman DM, Chen Y, Sostek M. Comparison of the effects of intravenously and orally administered esomeprazole on acid output in patients with symptoms of gastro-oesophageal reflux disease. Aliment Pharmacol Ther. Nov 1. 2005;22(9):813-821. [pmid: 16225490].
Miehlke S, Madisch A, Kirsch C, et al. Intragastric acidity during treatment with esomeprazole 40 mg twice daily or pantoprazole 40 mg twice daily--a randomized, two-way crossover study. Aliment Pharmacol Ther. Apr 15. 2005;21(8):963-967. [pmid: 15813831].
Miner PB Jr, Allgood LD, Grender JM. Comparison of gastric pH with omeprazole magnesium 20.6 mg (Prilosec OTC) o.m. famotidine 10 mg (Pepcid AC) b.d. and famotidine 20 mg b.d. over 14 days of treatment. Aliment Pharmacol Ther. Jan 1. 2007;25(1):103-109. [pmid: 17229225].
Nielsen OH, Ainsworth M, Csillag C, Rask-Madsen J. Systematic review: coxibs, non-steroidal anti-inflammatory drugs or no cyclooxygenase inhibitors in gastroenterological high-risk patients?. Aliment Pharmacol Ther. Jan 1. 2006;23(1):27-33. [pmid: 16393277].
Orr WC, Goodrich S, Robert J. The effect of acid suppression on sleep patterns and sleep-related gastro-oesophageal reflux. Aliment Pharmacol Ther. Jan 15. 2005;21(2):103-108. [pmid: 15679759].
Otaka M, Jin M, Odashima M, et al. New strategy of therapy for functional dyspepsia using famotidine, mosapride and amitriptyline. Aliment Pharmacol Ther. Jun. 2005;21(Suppl 2):42-46. [pmid: 15943846].
Ott EA, Mazzoleni LE, Edelweiss MI, et al. Helicobacter pylori eradication does not cause reflux oesophagitis in functional dyspeptic patients: a randomized, investigator-blinded, placebo-controlled trial. Aliment Pharmacol Ther. May 15. 2005;21(10):1231-1239. [pmid: 15882244].
Pace F, Negrini C, Wiklund I, Rossi C, Savarino V. Quality of life in acute and maintenance treatment of non-erosive and mild erosive gastro-oesophageal reflux disease. Aliment Pharmacol Ther. Aug 15. 2005;22(4):349-356. [pmid: 16098002].
Pace F, Tonini M, Pallotta S, Molteni P, Porro GB. Systematic review: maintenance treatment of gastro-oesophageal reflux disease with proton pump inhibitors taken 'on-demand'. Aliment Pharmacol Ther. Jul 15. 2007;26(2):195-204.
Pellegrini M, Urso R, Giorgi G, Bayeli PF, Marzocca G, Cerretani D. Is a long-term ranitidine-based triple therapy against Helicobacter pylori only a heritage of the past? A prospective, randomized clinicopharmacological study. Aliment Pharmacol Ther. Aug 15. 2005;22(4):343-348. [pmid: 16098001].
Piesman M, Hwang I, Maydonovitch C, Wong RK. Nocturnal reflux episodes following the administration of a standardized meal. Does timing matter?. Am J Gastroenterol. Oct. 2007;102(10):2128-2134. [pmid: 17573791].
Pilichiewicz AN, Horowitz M, Russo A, et al. Effects of Iberogast on proximal gastric volume, antropyloroduodenal motility and gastric emptying in healthy men. Am J Gastroenterol. Jun. 2007;102(6):1276-1283. [pmid: 17378904].
Ponce J, Vegazo O, Beltran B, et al. Prevalence of gastro-oesophageal reflux disease in Spain and associated factors. Aliment Pharmacol Ther. Jan 1. 2006;23(1):175-184. [pmid: 16393295].
Qadeer MA, Phillips CO, Lopez AR, et al. Proton pump inhibitor therapy for suspected GERD-related chronic laryngitis: a meta-analysis of randomized controlled trials. Am J Gastroenterol. Nov. 2006;101(11):2646-2654. [pmid: 17037995].
Raghunath AS, Hungin AP, Mason J, Jackson W. Helicobacter pylori eradication in long-term proton pump inhibitor users in primary care: a randomized controlled trial. Aliment Pharmacol Ther. Mar 1. 2007;25(5):585-592. [pmid: 17305759].
Ramage JI Jr, Rumalla A, Baron TH, et al. A prospective, randomized, double-blind, placebo-controlled trial of endoscopic steroid injection therapy for recalcitrant esophageal peptic strictures. Am J Gastroenterol. Nov. 2005;100(11):2419-2425. [pmid: 16279894].
Regula J, Butruk E, Dekkers CP, et al. Prevention of NSAID-associated gastrointestinal lesions: a comparison study pantoprazole versus omeprazole. Am J Gastroenterol. Aug. 2006;101(8):1747-1755. [pmid: 16817839].
Rodriguez-Stanley S, Zubaidi S, Proskin HM, Kralstein JR, Shetzline MA, Miner PB Jr. Effect of tegaserod on esophageal pain threshold, regurgitation, and symptom relief in patients with functional heartburn and mechanical sensitivity. Clin Gastroenterol Hepatol. Apr. 2006;4(4):442-450. [pmid: 16616348].
Rothstein R, Filipi C, Caca K, et al. Endoscopic full-thickness plication for the treatment of gastroesophageal reflux disease: A randomized, sham-controlled trial. Gastroenterology. Sep. 2006;131(3):704-712. [pmid: 16952539].
Schey R, Dickman R, Parthasarathy S, et al. Sleep deprivation is hyperalgesic in patients with gastroesophageal reflux disease. Gastroenterology. Dec. 2007;133(6):1787-1795. [pmid: 18054551].
Schwartz MP, Wellink H, Gooszen HG, Conchillo JM, Samsom M, Smout AJ. Endoscopic gastroplication for the treatment of gastro-oesophageal reflux disease: a randomised, sham-controlled trial. Gut. Jan. 2007;56(1):20-28. [pmid: 16763053].
Seno H, Nakase H, Chiba T. Usefulness of famotidine in functional dyspepsia patient treatment: comparison among prokinetic, acid suppression and antianxiety therapies. Aliment Pharmacol Ther. Jun. 2005;21(Suppl 2):32-36. [pmid: 15943844].
Sgouros SN, Vlachogiannakos J, Karamanolis G, et al. Long-term acid suppressive therapy may prevent the relapse of lower esophageal (Schatzki's) rings: a prospective, randomized, placebo-controlled study. Am J Gastroenterol. Sep. 2005;100(9):1929-1934. [pmid: 16128935].
Sharma P, Wani S, Rastogi A, et al. The diagnostic accuracy of esophageal capsule endoscopy in patients with gastroesophageal reflux disease and Barrett's esophagus: a blinded, prospective study. Am J Gastroenterol. Mar. 2008;103(3):525-532. [pmid: 17459025].
Sheu BS, Kao AW, Cheng HC, et al. Esomeprazole 40 mg twice daily in triple therapy and the efficacy of Helicobacter pylori eradication related to CYP2C19 metabolism. Aliment Pharmacol Ther. Feb 1. 2005;21(3):283-288. [pmid: 15691303].
Sjostedt S, Befrits R, Sylvan A, et al. Daily treatment with esomeprazole is superior to that taken on-demand for maintenance of healed erosive oesophagitis. Aliment Pharmacol Ther. Aug 1. 2005;22(3):183-191. [pmid: 16091055].
Spechler SJ. Screening and surveillance for complications related to gastroesophageal reflux disease. Am J Med. Dec. 3. 2001;111(Suppl 8A):130S-136S. [pmid: 11749938].
Spechler SJ, Sharma P, Traxler B, Levine D, Falk GW. Gastric and esophageal pH in patients with Barrett's esophagus treated with three esomeprazole dosages: a randomized, double-blind, crossover trial. Am J Gastroenterol. Sep. 2006;101(9):1964-1971. [pmid: 16848802].
Talley NJ, Armstrong D, Junghard O, Wiklund I. Predictors of treatment response in patients with non-erosive reflux disease. Aliment Pharmacol Ther. Jul 15. 2006;24(2):371-376. [pmid: 16842464].
Talley NJ, Choung RS, Camilleri M, Dierkhising RA, Zinsmeister AR. Asimadoline, a kappa-opioid agonist, and satiation in functional dyspepsia. Aliment Pharmacol Ther. Jun 1. 2008;27(11):1122-1131. [pmid: 18331462].
Talley NJ, Locke GR, Lahr BD, et al. Predictors of the placebo response in functional dyspepsia. Aliment Pharmacol Ther. Apr 1. 2006;23(7):923-936. [pmid: 16573795].
Talley NJ, Tack J, Ptak T, Gupta R, Giguere M. Itopride in functional dyspepsia: results of two phase III multicentre, randomised, double-blind, placebo-controlled trials. Gut. Jun. 2008;57(6):740-746. [pmid: 17965059].
Talley NJ, Vakil N, Lauritsen K, et al. Randomized-controlled trial of esomeprazole in functional dyspepsia patients with epigastric pain or burning: does a 1-week trial of acid suppression predict symptom response?. Aliment Pharmacol Ther. Sep 1. 2007;26(5):673-682. [pmid: 17697201].
Thumshirn M, Fruehauf H, Stutz B, Tougas G, Salter J, Fried M. Clinical trial: effects of tegaserod on gastric motor and sensory function in patients with functional dyspepsia. Aliment Pharmacol Ther. Nov 15. 2007;26(10):1399-1407. [pmid: 17892526].
Tougas G, Earnest DL, Chen Y, Vanderkoy C, Rojavin M. Omeprazole delays gastric emptying in healthy volunteers: an effect prevented by tegaserod. Aliment Pharmacol Ther. Jul 1. 2005;22(1):59-65. [pmid: 15963081].
Tran T, Lowry AM, El-Serag HB. Meta-analysis: the efficacy of over-the-counter gastro-oesophageal reflux disease therapies. Aliment Pharmacol Ther. Jan 15. 2007;25(2):143-153. [pmid: 17229239].
Triadafilopoulos G, Kaur B, Sood S, Traxler B, Levine D, Weston A. The effects of esomeprazole combined with aspirin or rofecoxib on prostaglandin E2 production in patients with Barrett's oesophagus. Aliment Pharmacol Ther. Apr 1. 2006;23(7):997-1005. [pmid: 16573802].
Tutuian R, Mainie I, Allan R, et al. Effects of a 5-HT(4) receptor agonist on oesophageal function and gastro-oesophageal reflux: studies using combined impedance-manometry and combined impedance-pH. Aliment Pharmacol Ther. Jul 1. 2006;24(1):155-162. [pmid: 16803614].
Tytgat GN, Simoneau G. Clinical and laboratory studies of the antacid and raft-forming properties of Rennie alginate suspension. Aliment Pharmacol Ther. Mar 15. 2006;23(6):759-765. [pmid: 16556178].
Vakil N, Guda N, Partington S. The effect of over-the-counter ranitidine 75 mg on night-time heartburn in patients with erosive oesophagitis on daily proton pump inhibitor maintenance therapy. Aliment Pharmacol Ther. Mar 1. 2006;23(5):649-653. [pmid: 16480404].
Vakil N, Laine L, Talley NJ, et al. Tegaserod treatment for dysmotility-like functional dyspepsia: results of two randomized, controlled trials. Am J Gastroenterol. Aug. 2008;103(8):1906-1919. [pmid: 18616658].
Vakil N, Talley NJ, Stolte M, Sundin M, Junghard O, Bolling-Sternevald E. Patterns of gastritis and the effect of eradicating Helicobacter pylori on gastro-oesophageal reflux disease in Western patients with non-ulcer dyspepsia. Aliment Pharmacol Ther. Jul 1. 2006;24(1):55-63. [pmid: 16803603].
van Kerkhoven LA, Laheij RJ, Aparicio N, et al. Effect of the antidepressant venlafaxine in functional dyspepsia: a randomized, double-blind, placebo-controlled trial. Clin Gastroenterol Hepatol. Jul. 2008;6(7):746-752. quiz 718. [pmid: 18424191].
Van Lelyveld N, Ter Linde J, Baron A, Mundt M, Wajs E, Samsom M. The 5-HT4 antagonist R216073 does not affect gastric motor and sensory function in patients with functional dyspepsia. Aliment Pharmacol Ther. Aug 15. 2006;24(4):669-677. [pmid: 16827813].
van Zanten SV, Armstrong D, Chiba N, et al. Esomeprazole 40 mg once a day in patients with functional dyspepsia: the randomized, placebo-controlled "ENTER" trial. Am J Gastroenterol. Sep. 2006;101(9):2096-2106. [pmid: 16817845].
van Zanten SV, Flook N, Talley NJ, et al. One-week acid suppression trial in uninvestigated dyspepsia patients with epigastric pain or burning to predict response to 8 weeks' treatment with esomeprazole: a randomized, placebo-controlled study. Aliment Pharmacol Ther. Sep 1. 2007;26(5):665-672. [pmid: 17697200].
Veldhuyzen van Zanten SJ, Chiba N, Armstrong D, et al. A randomized trial comparing omeprazole, ranitidine, cisapride, or placebo in helicobacter pylori negative, primary care patients with dyspepsia: the CADET-HN Study. Am J Gastroenterol. Jul. 2005;100(7):1477-1488. [pmid: 15984968].
von Arnim U, Peitz U, Vinson B, Gundermann KJ, Malfertheiner P. STW 5, a phytopharmacon for patients with functional dyspepsia: results of a multicenter, placebo-controlled double-blind study. Am J Gastroenterol. Jun. 2007;102(6):1268-1275. [pmid: 17531013].
Wada T, Sasaki M, Kataoka H, et al. Efficacy of famotidine and omeprazole in healing symptoms of non-erosive gastro-oesophageal reflux disease: randomized-controlled study of gastro-oesophageal reflux disease. Aliment Pharmacol Ther. Jun. 2005;21(Suppl 2):2-9.
Wakelin DE, Sampliner RE. Endoscopic antireflux procedures: a good wrap?. Clin Gastroenterol Hepatol. Sep. 2005;3(9):831-839. [pmid: 16234018].
Wang WH, Huang JQ, Zheng GF, et al. Effects of proton-pump inhibitors on functional dyspepsia: a meta-analysis of randomized placebo-controlled trials. Clin Gastroenterol Hepatol. Feb. 2007;5(2):178-185. quiz 140. [pmid: 17174612].
Warrington S, Baisley K, Lee D, et al. Pharmacodynamic effects of single doses of rabeprazole 20 mg and pantoprazole 40 mg in patients with GERD and nocturnal heartburn. Aliment Pharmacol Ther. Feb 15. 2007;25(4):511-517. [pmid: 17270007].
Wenner J, Johnsson F, Johansson J, Oberg S. Wireless esophageal pH monitoring is better tolerated than the catheter-based technique: results from a randomized cross-over trial. Am J Gastroenterol. Feb. 2007;102(2):239-245. [pmid: 17100971].
Wo JM, Koopman J, Harrell SP, Parker K, Winstead W, Lentsch E. Double-blind, placebo-controlled trial with single-dose pantoprazole for laryngopharyngeal reflux. Am J Gastroenterol. Sep. 2006;101(9):1972-1978. quiz 2169. [pmid: 16968502].
Yeomans N, Lanas A, Labenz J, et al. Efficacy of Esomeprazole (20 mg Once Daily) for Reducing the Risk of Gastroduodenal Ulcers Associated With Continuous Use of Low-Dose Aspirin. Am J Gastroenterol. Jun. 30. 2008.
Zacny J, Zamakhshary M, Sketris I, Veldhuyzen van Zanten S. Systematic review: the efficacy of intermittent and on–demand therapy with histamine H2-receptor antagonists or proton pump inhibitors for gastro-oesophageal reflux disease patients. Aliment Pharmacol Ther. Jun 1. 2005;21(11):1299-1312. [pmid: 15932360].
Zheng Z, Margolis KL, Liu S, Tinker LF, Ye W. Effects of estrogen with and without progestin and obesity on symptomatic gastroesophageal reflux. Gastroenterology. Jul. 2008;135(1):72-81. [pmid: 18502208].

## CER 2. Effectiveness of Noninvasive Tests for Breast Abnormalities

For this assessment, a limited literature search was conducted for the years 2005–2008. This search included the five generalist journals listed in the Methods and seven specialty journals (those most frequently cited in the original CER): CA: A Cancer Journal for Clinicians, Radiological Clinics of North America, Journal of Nuclear Medicine, European Journal of Nuclear Medicine, Radiology, Journal of Magnetic Resonance Imaging, and Journal of Ultrasound Medicine. The search identified 1,465 titles, of which 54 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of the 54 selected for further review, 20 were abstracted. The remaining articles were rejected because they had already been included in the earlier report or did not include a comparison of interest.

We consulted the project lead, two members of the TEP and one other expert for their assessments. Of these four individuals, one responded.

Table 2.2 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.2 CER 2. Effectiveness of Noninvasive Diagnostic Tests for Breast Abnormalities: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SC EPC
Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | Only one expert provided input | Conclusion from SC EPC
Key Question 1: What are the sensitivity and specificity of the tests for diagnosis of breast cancer in women presenting with an abnormal mammogram or a palpable breast abnormality?
To place the tests’ accuracy information into perspective, an average woman in the U.S. who has an abnormal mammogram requiring a biopsy for evaluation has approximately a 20-percent risk of cancer. For women at this average level of risk of cancer after an abnormal mammogram, based upon the tests' negative likelihood ratios: * For every 1,000 women who had a negative PET scan, about 924 women would have avoided an unnecessary biopsy, but 76 women would have missed cancers. * For every 1,000 women who had a negative scintimammogram, about 907 women would have avoided an unnecessary biopsy, but 93 women would have missed cancers. (These numbers are for nonpalpable lesions only; numbers could not be calculated for all lesions.) * For every 1,000 women who had a negative MRI, about 962 women would have avoided an unnecessary biopsy, but 38 women would have missed cancers. * For every 1,000 women who had a negative US, about 950 women For every 1,000 women who had a negative US, about 950 women would have avoided an unnecessary biopsy, but 50 women would have missed cancers. | A meta-analysis of 44 studies of magnetic resonance imaging (MRI) in patients suspected of having breast cancer estimated the sensitivity at 0.90% and the specificity at 72% (Peters, 2008). | No new information. | One expert agreed that the conclusion is still valid. | It is difficult to estimate whether this conclusion is still valid or not, since it consists of calculations made based on operating characteristics of the test with “average” level of cancer risk. Using data from the Peters, 2008 meta-analysis, the “missed cancers” number would be 20, not 38. Therefore, this conclusion is possibly out of date, although probably modestly so.
Although all of the technologies evaluated could reduce the need for biopsy in women with an abnormal mammogram who do not have cancer, each would miss some cancers. | No literature will change this conclusion, since there is no test with 100% sensitivity. | No new information. | One expert agreed that the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 2: For women with relevant demographic risk factors (e.g., age, family history) and clinical risk factors (e.g., Breast Imaging Reporting and Data System [BIRADS] status or morphologic characteristics of the lesion), what are the positive and negative predictive values of the above diagnostic tests (Magnetic Resonance Imaging, Positron Emission Tomography, Scintimammography, or Ultrasound)?
In general, the higher a woman’s risk of cancer is before undergoing a noninvasive test, the higher is the risk that she has cancer even if the test is negative. If a less than 2-percent risk of having breast cancer with a negative diagnostic test is considered an acceptable level of risk for a diagnostic test to reliably preclude biopsy, none of these tests was sufficiently accurate to replace biopsy for women at average risk of breast cancer. | A systematic review of MRI to screen women at high risk for breast cancer included 11 studies and the summary negative likelihood ratio was 0.70 (Warner, 2008). The American Cancer Society released new guidelines for the use of MRI as an adjunct to mammography that recommended its use in women at increased risk (Saslow, 2008). A study of 969 women with breast cancer assessed the utility of MRI of the contralateral breast, which had no abnormalities on clinical examination or mammography. MRI detected breast cancer in 30 women (3.1%). The sensitivity was 91%, the specificity was 88%, and the negative predictive value of MRI was 99% (Lehman, 2007). A group of 2,809 women at elevated risk of breast cancer and with heterogeneously dense breast tissue were randomized to receive screening with mammography and ultrasound (US) or with mammography alone. The additional yield of added US was 4.2 cancers per 1000 women screened. The diagnostic accuracy of mammography alone was 0.78 and this increased to 0.91 with the addition of ultrasound (Berg, 2008). | No new information. | One expert noted that there might be some new evidence on MRI, particularly for certain subgroups of women. | Conclusion is probably out of date and this portion of the CER may need updating based on new data on MRI and US.
Key Question 3: Are there other factors that affect the accuracy or acceptability of the tests considered in Questions 1 and 2?
Based on results for only nonpalpable lesions (usually detected by mammography), data were insufficient to estimate the accuracy of PET scanning, MRI, or US. Scintimammography was not sufficiently accurate to avoid biopsy in women at average risk as judged by the acceptability standard of less than a 2-percent risk of breast cancer with a negative diagnostic test. Based on results for only palpable lesions, data were insufficient to estimate the accuracy of PET scanning, MRI, ultrasound, and scintimammography. | New meta-analysis reports sensitivities and specificities for MRI, Lehman, 2008, although the ability to separate results based on non-palpable versus palpable lesions is unknown | No new information. | One expert said that there wasn't really a conclusion and does not think sufficient evidence is available to reach one. | Conclusion is possibly out of date and this portion of the CER may need updating based on the new meta-analysis. It would need to be reviewed to assess whether data can be stratified.
Are there new data that could inform the key questions that might not be addressed in the conclusions? New technologies such as proton MR spectroscopy (Tozaki, 2008) and ultrasound elastography (Zhi, 2007) continue to appear; whether data are sufficient to justify adding these to the CER is not known.

Legend: BIRADS: Breast Imaging Reporting and Data System; MRI: magnetic resonance imaging; PET: positron emission tomography; US: ultrasound

### References

Berg WA, Blume JD, Cormack JB, et al. Combined screening with ultrasound and mammography vs mammography alone in women at elevated risk of breast cancer. JAMA. May 14. 2008;299(18):2151-2163. [pmid: 18477782].
Berman CG. Recent advances in breast-specific imaging. Cancer Control. Oct. 2007;14(4):338-349. [pmid: 17914334].
Dewey M, Martus P. MRI breast screening. Lancet. Apr. 26. 2008;371(9622):1415-1416. author reply 1416.
Elmore JG, Armstrong K, Lehman CD, Fletcher SW. Screening for breast cancer. JAMA. Mar 9. 2005;293(10):1245-1256. [pmid: 15755947].
Garrido-Laguna I, Fernandez Hidalgo O, Garcia Foncillas J. MRI evaluation of breast cancer. N Engl J Med. Jul. 12. 2007;357(2):191. author reply 193.
Hall FM. The rise and impending decline of screening mammography. Radiology. Jun. 2008;247(3):597-601. [pmid: 18487527].
Kuhl CK. The "coming of age" of nonmammographic screening for breast cancer. JAMA. May 14. 2008;299(18):2203-2205. [pmid: 18477789].
Kuhl CK, Schrading S, Bieling HB, et al. MRI for diagnosis of pure ductal carcinoma in situ: a prospective observational study. Lancet. Aug 11. 2007;370(9586):485-492. [pmid: 17693177].
Lehman CD, Gatsonis C, Kuhl CK, et al. MRI evaluation of the contralateral breast in women with recently diagnosed breast cancer. N Engl J Med. Mar 29. 2007;356(13):1295-1303. [pmid: 17392300].
Mitka M. New screening methods offer hope for more accurate breast cancer detection. JAMA. Jan 30. 2008;299(4):397-398. [pmid: 18230772].
Morris EA. Diagnostic breast MR imaging: current status and future directions. Radiol Clin North Am. Sep. 2007;45(5):863-880. vii. [pmid: 17888774].
Peters NH, Borel Rinkes IH, Zuithoff NP, Mali WP, Moons KG, Peeters PH. Meta-analysis of MR imaging in the diagnosis of breast lesions. Radiology. Jan. 2008;246(1):116-124. [pmid: 18024435].
Sakamoto N, Tozaki M, Higa K, et al. Categorization of non-mass-like breast lesions detected by MRI. Breast Cancer. 2008;15(3):241-246. [pmid: 18224381].
Saslow D, Boetes C, Burke W, et al. American Cancer Society guidelines for breast screening with MRI as an adjunct to mammography. CA Cancer J Clin. Mar-Apr. 2007;57(2):75-89. [pmid: 17392385].
Smith RA. The evolving role of MRI in the detection and evaluation of breast cancer. N Engl J Med. Mar 29. 2007;356(13):1362-1364. [pmid: 17392307].
Thorat MA. Should we undertake an MRI breast screening trial. Lancet. Dec. 8. 2007;370:9603-1902. author reply 1903–1904.
Tozaki M. Proton MR spectroscopy of the breast. Breast Cancer. 2008;15(3):218-223. [pmid: 18443899].
Warner E, Messersmith H, Causer P, Eisen A, Shumak R, Plewes D. Systematic review: using magnetic resonance imaging to screen women at high risk for breast cancer. Ann Intern Med. May 6. 2008;148(9):671-679. [pmid: 18458280].
Yang W, Dempsey PJ. Diagnostic breast ultrasound: current status and future directions. Radiol Clin North Am. Sep. 2007;45(5):845-861. vii. [pmid: 17888773].
Zhi H, Ou B, Luo BM, Feng X, Wen YL, Yang HY. Comparison of ultrasound elastography, mammography, and sonography in the diagnosis of solid breast lesions. J Ultrasound Med. Jun. 2007;26(6):807-81. [pmid: 17526612].

## CER 3. Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment

For this assessment, a limited literature search was conducted for the years 2004-2008. This search included the five generalist journals listed in the Methods and five specialty journals (as recommended by the subject matter experts): Cancer, Journal of Clinical Oncology, Annals of Oncology, Oncology, and British Journal of Cancer.

The search identified 94 titles, of which 24 were obtained in full text for further review. The remaining 70 titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of the 24 selected for further review, 16 were abstracted into an evidence table (Attachment II). The remaining articles were rejected because they had already been included in the earlier report or did not include a comparison of interest. An additional four articles were subsequently reviewed and added at the suggestion of the experts.

We consulted the project lead, 5 members of the TEP, and three additional experts for their assessments. Of these 9 individuals, four responded.

Table 2.3 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.3 CER 3. Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SCEPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SCEPC
Conclusions From CER Executive Summary | Summary of SCEPC Literature Search | FDA/Health Canada Info | EPC Investigator, 3 Other Experts: | Conclusion from SCEPC
Key Question 1: What are the comparative efficacy and safety of epoetin (alfa or beta) and darbepoetin?
The evidence does not show any clinically significant difference between epoetin and darbepoetin in hemoglobin response, transfusion reduction, and thromboembolic events (TEE). For each of the above outcomes, more evidence is available on epoetin than darbepoetin. | For hematologic response, no new studies compared epoetin to darbepoetin. 3 randomized controlled trial (RCT)s of epoetin A, 1 trial of epoetin B, and 2 trials of darbepoetin showed increases or smaller decreases in hemoglobin (Hb) compared with placebo controls; (Wright, 2007; Wilkinson, 2006; Razzouk, 2006; Aapro, 2008b; Pirker, 2006; Norager, 2006) 1 RCT of epoetin A vs. amifostine showed smaller reduction in Hb with epoetin A (Han, 2008). For rates of transfusion, 1 RCT compared epoetin to darbepoetin showed darbepoetin reduced transfusion incidence to a non-significantly greater degree than epoetin (Glaspy, 2006). 2 RCTs of epoetin A showed significant reduction in need for transfusion (including one study in children)(Wilkinson, 2006; Razzouk, 2006); 1 RCT of Darbepoetin showed non-significant decrease in need for transfusion (Smith, 2008) and 1 showed a significant decrease (Pirker, 2008). For TEE, 2 meta-analyses and 1 open-label multi- center RCT of epoetin B showed increased incidence of TEE vs. placebo, although event rates varied widely among treated and untreated patients (Aapro, 2008a; Aapro, 2006; Aapro, 2008b). No study showed an effect on TEE- related mortality or serious TEEs. | At the ODAC meeting in March 2008, FDA presented data on 5 new studies (4 darbepoetin and 1 epoetin) that showed evidence of tumor progression or worse survival in some patient populations. FDA Medwatch 1/08/07 revised Box Label for epoetin to read "WARNINGS: INCREASED MORTALITY, SERIOUS CARDIOVASCULAR and THROMBOEMBOLIC EVENTS, and TUMOR PROGRESSION. To minimize these risks, as well as the risk of serious cardio- and thrombovascular events,; - Use the lowest dose needed to avoid red blood cell transfusions.; - Use only for treatment of anemia due to concomitant myelosuppressive chemotherapy.; - Discontinue following the completion of a chemotherapy course.; Perisurgery: PROCRIT/EPOGEN® increased the rate of deep venous thromboses in patients not receiving prophylactic anticoagulation. Consider deep venous thrombosis prophylaxis.” | Three experts judged this conclusion is still valid. The fourth said it is probably still valid; however: “although no new evidence that I am aware of regarding clinical differences in safety and efficacy of the two drugs, a number of new studies have raised concerns regarding the safety and efficacy of the class that have led to new FDA labeling and changes in reimbursement policy. At the ODAC meeting in March 2008, FDA presented data on 5 new studies (4 darbepoetin and 1 epoetin) that showed evidence of tumor progression or worse survival in some patient populations.” | Conclusion is possibly out of date and this portion of the CER may need updating, based on new data presented to the FDA and difference in expert opinion.
The evidence is not sufficient for conclusions on effects of either epoetin or darbepoetin on quality of life (QoL), tumor response and progression, survival, or adverse outcomes other than TEE. Trials did not completely or consistently report quality of life (QoL) results, so 12 potentially relevant studies were unusable for this analysis, and quantitative analysis could not be performed for the 15 remaining studies. Overall, QoL measures tended to favor treatment with epoetin or darbepoetin… | Epoetin A significantly improved QoL as measured by median CLAS scores (energy level, ability to do daily activities, overall QoL) (Wilkinson, 2006); Epoetin A did not significantly improve mean PedsQL-GCS generic score and cancer specific score in children, but change in Hb correlated with PedsQL-GCS total score in the epoetin-treated group (Razzouk, 2006); Darbepoetin significantly improved work capacity compared to placebo but did not affect fatigue, postural sway, or QoL (Norager, 2006). | No new information. | No opinions provided by experts | Conclusion is still valid and this portion of the CER does not need updating.
The limited evidence available does not suggest that erythropoietic stimulants improve solid tumor response to a concurrent course of cancer therapy. Whether erythropoietic stimulants accelerate progression of some cancers, as reported by one study is uncertain. | Two meta-analyses of epoetin B showed similar effects on tumor response and disease progression. One showed a slight beneficial effect on disease progression (Aapro, 2006); the second showed a trend toward a beneficial effect on tumor progression (Aapro, 2008a). A new review states that both epoetin and darbepoetin have been linked to decreased survival (Glaspy, 2009). | (See reference to FDA Medwatch Revised Box Label above) | Three experts judged that the conclusion remains valid, but with the following comments: “The first part remains true: Erythropoiesis stimulating agents (ESAs) do not improve solid tumor responses (this is now supported by more and better- quality evidence); however, there are now several additional studies suggesting ESAs may accelerate progression of some cancers.” One expert cited a new review: “May be associated with adverse outcomes (Glaspy, 2009) ” “Increased tumor progression” ” (Henke, 2003; Leyland-Jones, 2005; Bennett, 2008) [Henke 2003 and Leyland-Jones 2005 were included in the original report] One expert judged that the conclusion is no longer valid: “New Evidence: Although uncertainty still remains on overall effect of ESAs on tumor progression, 5 new studies (4 darbepoetin and 1 epoetin) showed evidence of tumor progression or worse survival in some patient populations. Balance of evidence does not demonstrate any improvement in solid tumor response.” | Conclusion is out of date and this portion of the CER needs updating based on new data and agreement of expert opinion.
Of 40 RCTs reporting on survival, only seven were actually designed to assess effects on survival. No studies designed to test survival used epoetin or darbepoetin as currently recommended; rather, all seven trials sought to maintain Hb levels >12 g/dL. Two of the seven trials, one on metastatic breast cancer (n=939) and one on head and neck cancer (n=351), showed poorer overall survival for patients treated with epoetin; this prompted an FDA safety review in May 2004 and revised product labeling to indicate that clinicians should avoid targeting Hb concentrations above 12 g/dL. Of the other five trials, survival appeared poorer with erythropoietic stimulant in three and better in two, but most results were not statistically significant. Analysis of mortality in all 40 trials shows no overall benefit of darbepoetin or epoetin on survival. Neither higher than recommended target Hb nor any other single patient- or treatment-related factor explained why some trials showed a detriment in survival and others did not. | 2 RCTs and 2 meta-analyses showed no change in survival with epoetin A(Han, 2008) or epoetin B (Aapro, 2006; Aapro, 2008a; Aapro, 2008b) but the authors noted that the latter was underpowered to detect a difference; One multicenter RCT of epoetin A found a decrease in median survival, which resulted in early termination of the study (Wright, 2007). A new review reported that epoetin has been associated with reduced transfusion requirements and also with an increase in the risk for venous thromboembolism (VTE) and a decrease in survival rate. (Fenner and Ganser, 2008). | (See reference to FDA Medwatch Revised Box Label above) | One of the experts judged the conclusion to still be valid but provided a new reference (Fenner and Ganser, 2008). The remaining three judged it no longer valid and made the following comments: “There are several new trials with evidence of harm, but nearly all were stopped early by DSMBs.” Another expert stated: “Package Inserts 2008. Not related to hemoglobin level. 51 RCTs - meta-analysis, decreased survival with ESAs. Trials that included survival as 1st or secondary outcomes; (14 trials with 5,785 patients)-hazard ratio for mortality =1.18(1.04, 1.35). (Samaras, 2008 [RAND unable to locate reference]) “No longer valid: New Evidence: As mentioned previously, 5 new studies (4 darbepoetin and 1 epoetin) showed evidence of tumor progression or worse survival in some patient populations although indication or dose of ESAs or Hb used was not compared with current product labeling. FDA analysis of Hb achieved (as opposed to target) presented at March 2008 ODAC meeting raised concerns about Hb<12 as target and resulted in labeling change that Hb target should be to avoid a transfusion.” | Conclusion is probably out of date and this portion of the CER may need updating based on new data and the majority of expert opinion.
For other adverse events, reporting is incomplete, representing less than one- third of patients. Studies did not use consistent definitions of events and severity. Overall, adverse events were more frequent with epoetin or darbepoetin than control, but pooled results did not show statistically significant differences. | According to an updated systematic review of 57 studies by Bohlius and colleagues (the authors of this review), treatment with epoetin or darbepoetin increased the risk of thromboembolic events; although uncertainty remains regarding their effect on survival, caution is advised on their use with thrombogenic chemotherapeutic agents or in patients at high risk for thromboembolic events (Bohlius., 2006). A systematic review of Phase 3 trials assessing mortality associated with the use of ESAs to treat anemia among cancer patients found an increased risk of VTE and mortality (Bennett, 2008). | No new information. | One expert considered the conclusion still valid. Two did not and noted the following: “1.57-fold increased risk of VTE. (Bohlius, 2006)” “Several new meta- analyses have been published with statistically significant worsening in survival reported in Bennett, 2008.” | Conclusion is possibly out date and this portion of the CER may need updating based on differing expert opinion.
Key Question 2: How do alternative dosing strategies affect the comparative efficacy and safety of epoetin and darbepoetin?
For each of the following pairs of dosing strategies, one large trial reported no statistically significant difference between strategies: fixed-dose compared to dose based on weight, one trial each for epoetin and darbepoetin; fixed-dose epoetin administered weekly vs. thrice weekly; fixed dose epoetin administered weekly vs. every 3 weeks; and darbepoetin using an initial loading dose versus constant weight-based dosing regimens. The remaining 14 trials were too small to interpret. | Two RCTs compared the effect of administering darbepoetin with and without iron (sodium ferric gluconate or IV iron) on hematopoietic response to darbepoetin and transfusion rate among patients with Hb≤11: both studies found that iron co-administration improved hematopoietic response to darbepoetin (Pedrazzoli, 2008; Bastit, 2008), and one found decreased requirement for transfusions (Bastit, 2008). | (See reference to FDA Medwatch Revised Box Label above) | Two experts considered the conclusion still valid; two said they do not know. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 3: How do alternative thresholds for initiating treatment or alternative criteria for discontinuing therapy or duration of therapy affect the efficacy and safety of erythropoietic stimulants?
Three unblinded randomized trials, not yet published, compared using erythropoietic stimulant therapy soon after mild anemia developed vs. delaying treatment until Hb had fallen below a predefined threshold of moderate anemia. Comparisons were ~11 g/dL vs. 9 g/dL; ~11 g/dL vs. 10 g/dL; and ~13 g/dL vs. 10 g/dL. All patients in the mild anemia arms were treated with an erythropoietic stimulant; of patients in whom treatment was delayed until moderate anemia developed, 19 percent, 63 percent, and 44 percent, respectively, were treated with erythropoietic stimulant. Transfusion was more frequent when treatment was delayed until moderate anemia developed, but the difference was not statistically significant in any study. One trial reported a statistically significant increase in TEE among patients who were treated for mild anemia compared with those who were treated for moderate anemia. | One RCT (probably one of the ones originally reported as not yet published) found greater effects on Hb, QoL, and productivity when treatment was initiated early (baseline Hb 10-12 g/dL) (Straus, 2006). A systematic review of 11 RCTs comparing early and late erythropoietic intervention reported improved clinical benefit (in terms of Hb and transfusion incidence) from early treatment initiation (Lyman, 2006). | (See reference to FDA Medwatch Revised Box Label above) | One expert said the conclusion is probably still valid. One said it is not valid and provided the following comment” “Package inserts. No specific trigger or target hemoglobin level is advised.” One expert said the conclusion is no longer valid and provided the following evidence: “As mentioned previously, FDA analysis of Hb achieved (as opposed to target) presented at March 2008 ODAC meeting raised concerns about Hb<12 as target and resulted in labeling change that Hb target should be to avoid a transfusion.” | Conclusion is probably out of date and this portion of the CER may need updating based on new evidence and the majority of expert opinion.
Key Question 4: Are any patient characteristics at baseline or early hematologic changes useful to select patients or predict responses to treatment with erythropoietic stimulants?
Available evidence does not identify any single patient factor as clinically useful to guide treatment decisions. Potential predictive factors, measured at baseline (e.g., serum erythropoietin level or observed/predicted ratio [O/P ratio], serum ferritin) or early after starting treatment (e.g., Hb increase, serum ferritin, reticulocyte increase), were found to have either weak ability or no ability to discriminate between responders and nonresponders. Seven algorithms combining multiple factors, potentially more useful to predict Hb response, are each currently supported only by one study. The largest of these studies do not report sufficient predictive ability for any algorithm to establish clinical utility for selecting treatment. | A phase-III multi-center RCT compared the effect of darbepoetin to placebo in patients with active cancer who were not receiving or planning to receive cytotoxic chemotherapy or myelosuppressive radiotherapy. Although transfusion incidence decreased non-significantly, cardiovascular events, TEE, and mortality increased, and long-term survival decreased (Smith, 2008). Survival varied by sex, tumor type, and geographic region but these effects disappeared w/sensitivity analysis. | (See reference to FDA Medwatch Revised Box Label above) | One expert deemed the conclusion still valid. A second said that it is probably not valid and provided the following evidence “Contra- indicated in patients receiving potentially curative therapy. Package insert. Breast, lungs and head and neck cancers may be particularly risky. ODAC 2008.” | Conclusion is possibly out of date and this portion of the CER may need updating, based on differing expert opinion.
Are there new data that could inform the key questions that might not be addressed in the conclusions? One expert provided additional comments: The problem for doing a systematic review on this aspect of the evidence is that nearly all the new studies were terminated early by DSMBs because of safety concerns, well before they reached accrual targets. As a result, it seems unlikely to me that repeating the literature-based analyses with the added data would be any more conclusive than before. But another important issue here, and partly the reason why IPD meta-analysis seems the best approach going forward, is that an overall, across-the-board conclusion for all oncology patients may be misleading. The big advantage of IPD analysis in this particular situation is that, for each outcome, results can be evaluated separately for early- and advanced-stage patients, and separately for each of the most common malignancies.

Legend: DSMB: Data safety monitoring board; ESA: Erythropoiesis stimulating agent; Hb: Hemoglobin; ODAC: Oncology Drug Advisory Committee; QoL: Quality of life; RCT: Randomized controlled trial; TEE: Thromboembolic event; VTE: Venous thromboembolism

### References

Aapro M, Coiffier B, Dunst J, Osterborg A, Burger HU. Effect of treatment with epoetin beta on short-term tumour progression and survival in anaemic patients with cancer: A meta-analysis. Br J Cancer. 2006;95(11):1467-73. [pmid: 17117175].
Aapro M, Leonard RC, Barnadas A, Marangolo M, Untch M, Malamos N, Mayordomo J, Reichert D, Pedrini JL, Ukarma L, Scherhag A, Burger HU. Effect of once-weekly epoetin beta on survival in patients with metastatic breast cancer receiving anthracycline- and/or taxane-based chemotherapy: results of the Breast Cancer-Anemia and the Value of Erythropoietin (BRAVE) study. J Clin Oncol. 2008;26(4):592-8. [pmid: 18235117].
Aapro M, Scherhag A, Burger HU. Effect of treatment with epoetin-beta on survival, tumour progression and thromboembolic events in patients with cancer: an updated meta-analysis of 12 randomised controlled studies including 2301 patients. Br J Cancer. 2008;99(1):14-22. [pmid: 18542079].
Bastit L, Vandebroek A, Altintas S, Gaede B, Pinter T, Suto TS, Mossman TW, Smith KE, Vansteenkiste JF. Randomized, multicenter, controlled trial comparing the efficacy and safety of darbepoetin alpha administered every 3 weeks with or without intravenous iron in patients with chemotherapy-induced anemia. J Clin Oncol. 2008;26(10):1611-8. [pmid: 18375890].
Bennett CL, Silver SM, Djulbegovic B, Samaras AT, Blau CA, Gleason KJ, Barnato SE, Elverman KM, Courtney DM, McKoy JM, Edwards BJ, Tigue CT, RAisch EW, Yarnold PR, Dorr DA, Kuzel TM, Tallman MS, Trifilio SM, West DP, Lai SY, Henke M. Venous Thromboembolism and mortality associated with recombinant erythropoietin and darbepoetin administration for the treatment of cancer-associated anemia. JAMA. February. 27. 2008;299(8):914-24. [pmid: 18314434].
Bohlius J, Wilson J, Seidenfeld J, Piper M, Schwarzer G, Sandercock J, Trelle S, Weingart O, Bayliss S, Djulbegovic B, Bennett CL, Langensiepen S, Hyde C, Engert A. Recombinant human erythropoietins and cancer patients: Updated meta-analysis of 57 studies including 9353 patients. J Nat’l Cancer Inst. May. 17. 2006;98(10).
Fenner MH, Ganser A. Epoetin in cancer-related anemia. Current Opinions in Oncology. 2008;20(6):685-89.
Glaspy JA. Erythropoetin in Cancer Patients. Annual Review of Medicine. 2009;60:181-92.
Glaspy J, Vadhan-Raj S, Patel R, Bosserman L, Hu E, Lloyd RE, Boccia RV, Tomita D, Rossi G. Randomized comparison of every-2-week darbepoetin alfa and weekly epoetin alfa for the treatment of chemotherapy-induced anemia: the 20030125 Study Group Trial. J Clin Oncol. 2006;24(15):2290-7. [pmid: 16710026].
Han HS, Han JY, Yu SY, Pyo HR, Kim HY, Cho KH, Lee DH, Kim HT, Lee JS. Randomized phase 2 study of subcutaneous amifostine versus epoetin-alpha given 3 times weekly during concurrent chemotherapy and hyperfractionated radiotherapy for limited-disease small cell lung cancer. Cancer. Oct 1. 2008;113(7):1623-31. [pmid: 18671241].
Lyman GH, Glaspy J. Are there clinical benefits with early erythropoietic intervention for chemotherapy-induced anemia? A systematic review. Cancer. 2006;106(1):223-33. [pmid: 16331597].
Norager CB, Jensen MB, Madsen MR, Qvist N, Laurberg S. Effect of darbepoetin alfa on physical function in patients undergoing surgery for colorectal cancer. A randomized, double-blind, placebo-controlled study. Oncology. 2006;71(3-4):212-20. [pmid: 17641543].
Pedrazzoli P, Farris A, Del Prete S, Del Gaizo F, Ferrari D, Bianchessi C, Colucci G, Desogus A, Gamucci T, Pappalardo A, Fornarini G, Pozzi P, Fabi A, Labianca R, Di Costanzo F, Secondino S, Crucitta E, Apolloni F, Del Santo A, Siena S. Randomized trial of intravenous iron supplementation in patients with chemotherapy-related anemia without iron deficiency treated with darbepoetin alpha. J Clin Oncol. 2008;26(10):1619-25. [pmid: 18375891].
Pirker R, Ramlau RA, Schuette W, Zatloukal P, Ferreira I, Lillie T, Vansteenkiste JF. Safety and efficacy of darbepoetin alpha in previously untreated extensive-stage small-cell lung cancer treated with platinum plus etoposide. J Clin Oncol. 2008;26(14):2342-9. [pmid: 18467726].
Razzouk BI, Hord JD, Hockenberry M, Hinds PS, Feusner J, Williams D, Rackoff WR. Double-blind, placebo-controlled study of quality of life, hematologic end points, and safety of weekly epoetin alfa in children with cancer receiving myelosuppressive chemotherapy. J Clin Oncol. 2006;24(22):3583-9. [pmid: 16877725].
Smith RE Jr, Aapro MS, Ludwig H, Pinter T, Smakal M, Ciuleanu TE, Chen L, Lillie T, Glaspy JA. Darbepoetin alpha for the treatment of anemia in patients with active cancer not receiving chemotherapy or radiotherapy: results of a phase III, multicenter, randomized, double-blind, placebo-controlled study. J Clin Oncol. 2008;26(7):1040-50. [pmid: 18227526].
Steensma DP, Molina R, Sloan JA, Nikcevich DA, Schaefer PL, Rowland KM Jr, Dentchev T, Novotny PJ, Tschetter LK, Alberts SR, Hogan TF, Law A, Loprinzi CL. Phase III study of two different dosing schedules of erythropoietin in anemic patients with cancer. J Clin Oncol. 2006;24(7):1079-89. [pmid: 16505427].
Straus DJ, Testa MA, Sarokhan BJ, Czuczman MS, Tulpule A, Turner RR, Riggs SA. Quality-of-life and health benefits of early treatment of mild anemia: a randomized trial of epoetin alfa in patients receiving chemotherapy for hematologic malignancies. Cancer. 2006;107(8):1909-17. [pmid: 16977654].
Wilkinson PM, Antonopoulos M, Lahousen M, Lind M, Kosmidis P. Epoetin alfa in platinum-treated ovarian cancer patients: results of a multinational, multicentre, randomised trial. Br J Cancer. 2006;94(7):947-54. [pmid: 16570051].
Wright JR, Ung YC, Julian JA, Pritchard KI, Whelan TJ, Smith C, Szechtman B, Roa W, Mulroy L, Rudinskas L, Gagnon B, Okawara GS, Levine MN. Randomized, double-blind, placebo-controlled trial of erythropoietin in non-small-cell lung cancer with disease-related anemia. J Clin Oncol. 2007;25(9):1027-32. [pmid: 17312332].

## CER 4. Comparative Effectiveness and Safety of Analgesics for Osteoarthritis

For this assessment, a limited literature search was conducted for the years 2005-2008. This search included the five generalist journals listed in the Methods and five specialty journals (as recommended by the subject matter experts): Rheumatology, Journal of Pain, British Journal of Rheumatology, Journal of Rheumatology, and Arthritis and Rheumatology. The search identified 49 titles, of which all were obtained as abstracts for further review. Fourteen full text articles were obtained and then abstracted. Thirty five articles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance.

We consulted the project lead, three members of the TEP, and two additional experts for their assessments. Of these 6 individuals, 4 responded.

Table 2.4 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.4 CER 4. Comparative Effectiveness and Safety of Analgesics for Osteoarthritis: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SCEPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SCEPC
Conclusions From CER Executive Summary | Summary of SCEPC Literature Search | FDA/Health Canada Info | EPC Investigator, 1 TEP Member, 2 Other Experts | Conclusion from SCEPC
Key Question 1: What are the comparative benefits and harms of treating osteoarthritis with oral medications or supplements? How do these benefits and harms change with dosage and duration of treatment, and what is the evidence that alternative dosage strategies, such as intermittent dosing and drug holidays, affect the benefits and harms of oral medication use? (Note: The only benefits considered under this question are improvements in osteoarthritis symptoms from long-term use. Evidence of harms associated with NSAID use includes long-term studies of these drugs for treating osteoarthritis or rheumatoid arthritis and for cancer prevention.)
There are no clear differences between various nonaspirin, nonselective NSAIDs or partially selective NSAIDs (meloxicam, nabumetone, etodolac) in efficacy for pain relief or improvement in function. | No new evidence. | No new information. | All experts agreed the conclusion is still valid. One expert states the conclusion needs to exclude acetaminophen and non-acetylated salicylates. | Conclusion is still valid and this portion of the CER does not need updating.
It is not clear whether celecoxib has fewer potential harms than nonselective NSAIDs when used longer than 3-6 months. | The Chan study is summarized below. | No new information. | One expert noted that you would need a large long-term trial to have enough power to examine this question, and s/he hasn’t heard of any studies that have done this. One expert noted that in a new RCT (Chan, 2007) in patients with prior GI bleeding, celecoxib plus a proton pump inhibitor (PPI) was safer than an NSAID plus PPI. One expert noted that a study has shown that etoricoxib has fewer harms (Multinational Etoricoxib and Diclofenac Arthritis Long-term [MEDAL] program). [Note: This study was included in the original CER] One expert noted that the conclusion needs to better account for celecoxib's dose and depends on whether aspirin is added. [Note: Those issues are addressed below] | Conclusion is probably out of date and this portion of the CER may need updating based on new data and expert opinion.
Celecoxib is associated with an increased risk of myocardial infarction. Most of the CV events with celecoxib were reported in two large polyp-prevention trials. | In a large cohort study, the relative risk of cardiovascular events in patients started on celecoxib compared to non users of NSAIDs was not significantly increased; however in subgroup analysis, several patient characteristics increased the risk for some CV events (Solomon DH, 2008) In a pooled analysis of 6 placebo-controlled RCTs, a differential risk of cardiovascular events was seen based on dosing regimen with the lowest hazard ratio in the 400 mg/day dose group (HR 1.1 with 95% CI 0.6 to 2.0) and the highest in the 400 mg twice a day dose group (HR 3.1) (Solomon SD, 2008). | No new information. | One expert thinks there may have been some data published from some Alzheimer’s prevention trials that were consistent with the original conclusion. One expert noted increased risk compared with placebo, but assumed SD Solomon's 2008 paper suggests that low dose in low-risk individuals is ok. | Conclusion is still valid and this portion of the CER does not need updating.
Etoricoxib is associated with fewer GI adverse events (perforations, symptomatic ulcers, and bleeds) than nonselective NSAIDs. Reviews of RCTs suggest that etoricoxib has a similar CV safety profile compared to other NSAIDs, with the possible exception of naproxen. Definitive conclusions are not possible because of small numbers of CV events. | Studies of etoricoxib vs. diclofenac in RA and OA reinforced the lower incidence of GI adverse events, but found no difference in serious complicated GI events. CV event incidence was similar, but studies found the 90 mg dose of etoricoxib to be associated with a significantly increased incidence of hypertension-related adverse events (Baraf, 2007; Laine, 2007; Cannon, 2006). | Etoricoxib: No new FDA information. | Three experts agreed the conclusion is still valid. One expert believes etoricoxib increases uncomplicated GI adverse events and appears to raise CV events. | Conclusion is possibly out of date and this portion of the CER may need updating based on diversity of expert opinion.
Results from one large trial found fewer adverse GI events with lumiracoxib than with naproxen and ibuprofen. Too few events have been reported in RCTs to accurately assess CV risk associated with lumiracoxib. | No new evidence. | Lumiracoxib refused approval by FDA 10/2007; Lumiracoxib was withdrawn from the Canadian market in 10/2007. Australia and New Zealand have also withdrawn lumiracoxib. Ibuprofen 3/2/2006 Revised label to add a boxed warning to address possible CV risks as well as known GI risks. | One expert agreed the conclusion is still valid; however, s/he suggests there may be new evidence about liver risk. | Conclusion is out of date and this portion of the CER needs updating since lumiracoxib is not FDA approved and has been withdrawn from the market of several countries.
Meloxicam - There were no significant differences in risks of serious GI events or CV risk. | No new evidence. | No new information. | Three experts agreed the conclusion is still valid. One expert suggests new McGettigan and Singh study (ACR abstract). [Note: The McGettigan study was included in the original CER; The Singh abstract was not found in our literature search] | Conclusion is still valid and this portion of the CER does not need updating.
Nabumetone or etodolac - There was insufficient evidence to make reliable judgments about relative GI safety and no evidence on CV safety. | No new evidence. | Etodolac 1/18/2006 - Revised label to add a boxed warning to address possible CV risks as well as known GI risks. | Experts agreed the conclusion is still valid | Conclusion is out of date and this portion of the CER needs updating to reflect change in labeling due to addition of FDA boxed warning label.
No clear difference in GI safety was found among nonselective NSAIDs at commonly used doses. | No new evidence. | No new information. | Experts agreed the conclusion is still valid | Conclusion is still valid and this portion of the CER does not need updating.
The CV safety of naproxen is moderately superior to that of any COX-2 selective NSAID. | No new evidence. | Naproxen Active FDA Safety Alert 12/2004- added the risk of cardiovascular and cerebrovascular events. | Three experts agreed the conclusion is still valid One expert states CV safety of naproxen depends on how it is taken; data from ADAPT (Alzheimer’s Disease Anti-inflammatory Prevention Trial) show diclofenac is worse. | Conclusion is still valid and this portion of the CER does not need updating.
The CV safety of nonselective NSAIDs other than naproxen (data primarily on ibuprofen and diclofenac) was similar to that of COX-2 selective NSAIDs. | No new evidence. | No new information | Three experts agreed the conclusion is still valid. One expert stated that CV safety of nonselective NSAIDs should separate the coxibs-lumping them is problematic. | Conclusion is still valid and this portion of the CER does not need updating.
Aspirin is associated with a lower risk of thromboembolic events and a higher risk of GI bleeds compared to placebo or nonuse when given in long-term prophylactic doses. There is insufficient evidence to assess the balance of GI and CV safety of higher dose aspirin as used for pain relief compared with nonaspirin NSAIDs. | No new evidence. | Aspirin: No new information. | Experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Almost no data are available on CV safety for salsalate. | No new evidence. | Salsalate: No new information. | Expert agreed the conclusion is still valid; one has unpublished data. | Conclusion is still valid and this portion of the CER does not need updating.
All NSAIDs and COX-2 inhibitors can cause or aggravate hypertension, congestive heart failure (CHF), edema, and impaired renal function | One study found etoricoxib 90 mg/d more likely than diclofenac to cause hypertension related adverse events (Baraf, 2007). | No new information. | One expert has a paper in press at Archives Int Med showing differences in acute kidney injury across agents. | Conclusion is possibly out of date and this portion of the CER may need updating based on upcoming publication of new evidence.
Among currently marketed NSAIDs, only diclofenac was associated with a significantly higher rate of liver-related discontinuations compared with placebo. | No new evidence. | Diclofenac 1/25/2006- Revised label to add a boxed warning to address possible cardiovascular risks as well as known gastrointestinal risks. | Three experts agreed the conclusion is still valid. One expert suggests Lumiracoxib also was associated with liver problems in the Therapeutic Arthritis Research and Gastrointestinal Event Trial (TARGET), (in press). [Note: Lumiracoxib was not approved for use in an FDA decision in 10/2007; it was withdrawn from the Australian and Canadian market due to concerns about liver problems] | Conclusion is still valid and this portion of the CER does not need updating.
Uncertainty remains regarding the comparative tolerability of salsalate and nonselective NSAIDs. | No new evidence. | Salsalate: No new information. | Experts agreed the conclusion is still valid | Conclusion is still valid and this portion of the CER does not need updating.
Acetaminophen is modestly inferior to NSAIDs for pain and function. Compared with NSAIDs, acetaminophen had fewer GI side effects and serious GI complications. Acetaminophen may be associated with modest increases in blood pressure and renal dysfunction. | No new evidence. | Acetaminophen: No new information. | Experts agreed the conclusion is still valid | Conclusion is still valid and this portion of the CER does not need updating.
One good-quality, prospective observational study found an increased risk of CV events with heavy use of acetaminophen that was similar to the risk associated with heavy use of NSAIDs. | No new evidence. | Acetaminophen: No new information. | One expert agreed the conclusion is still valid and noted the existing data were either from Nurses Health Study or Physicians Health Study so only a large, well- designed observational study could possibly call those results into question. | Conclusion is still valid and this portion of the CER does not need updating.
Glucosamine and chondroitin were generally well tolerated and no serious adverse events were reported in clinical trials. | In a large 6-month RCT of knee OA, glucosamine and chondroitin sulfate did not decrease pain significantly; however, in a secondary analysis, there was a suggestion of improvement in those with moderate to severe pain. (Clegg, 2006). Additionally, one RCT comparing glucosamine, acetaminophen, and placebo in knee OA found glucosamine more effective in reducing pain than placebo while acetaminophen did not demonstrate a significant improvement in functional status. (Herrero-Beaumont, 2007). | No new information. | Experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
We found no studies evaluating the GI or CV safety of alternative dosing strategies (such as alternate day dosing, once daily versus twice daily dosing, or periodic drug holidays). The risk of GI bleeding increases with higher doses of nonselective NSAIDs. | In a pooled analysis of 6 placebo controlled RCT, a differential risk of cardiovascular events were seen based on dosing regimen with lowest hazard ratio in the 400 mg a day dose (HR 1.1 with 95% CI 0.6 to 2.0), intermediate with 200 mg po BID and highest in 400 mg po BID dose (HR 3.1) (Solomon, 2008). | No new information. | Experts agreed the conclusion is still valid. | Conclusion is possibly out of date and this portion of the CER may need updating based on new data.
Higher doses of celecoxib were associated with increased CV risk, but could not determine the effects of dose on CV risk associated with rofecoxib due to low numbers of events at lower doses. Most trials of nonselective NSAIDs involved high doses. | No new information. | No new information. | Experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 2: Do the comparative benefits and harms of oral treatments for osteoarthritis vary for certain demographic and clinical subgroups of patients? * Demographic subgroups include age, sex, and race. * Coexisting diseases include hypertension, edema, ischemic heart disease, heart failure; peptic ulcer disease; history of previous bleeding due to NSAIDs. * Concomitant medication use includes anticoagulants.
GI and CV complication rates are higher among older patients and those with predisposing comorbid conditions, but there is no evidence that the relative safety of different NSAIDs varies according to baseline risk. Compared to nonuse of NSAIDs, one additional death per 1 year of use occurred for every 13 patients treated with rofecoxib, 14 with celecoxib, 45 with ibuprofen, and 24 with diclofenac in one large, population-based observational study of high- risk patients with acute myocardial infarction. There is no evidence that the comparative safety or efficacy of specific selective or nonselective NSAIDs varies depending on age, gender, or racial group, although data are sparse. | One study found predisposing patient characteristics to be age greater than or equal to 80 years, hypertension, prior MI, prior CVD, rheumatoid arthritis, chronic renal disease and COPD (Solomon DH, 2008). | No new information. | Three experts agreed the conclusion is still valid ; one cites Solomon DH, 2008. One expert was not clear on which studies support these recommendations. The same expert responded that the conclusion statement, "There is no evidence that the comparative safety or efficacy of specific selective or nonselective NSAIDs varies depending on age, gender, or racial group, although data are sparse" is odd. | Conclusion is still valid and this portion of the CER does not need updating.
Among patients who had a recent episode of upper GI bleeding, there is good evidence that rates of recurrent ulcer bleeding are high (around 5 percent after 6 months) in patients prescribed celecoxib or a nonselective NSAID plus a PPI. | This risk may be reduced by the use of a COX2 plus a PPI as the rate of recurrent GI bleed in a RCT of 441 patients was 0% compared with 8.9% for those on celecoxib alone with a median follow up of 13 months (Chan, 2007). | No new information. | Experts agreed the conclusion is still valid. One cites Chan, 2007. | Conclusion is still valid and this portion of the CER does not need updating.
Concomitant use of anticoagulants (e.g., warfarin) and any nonselective NSAID increases the risk of GI bleeding three- to sixfold compared to anticoagulants alone. Reliable conclusions about the safety of selective NSAIDs used with anticoagulants are not possible due to flaws in existing observational studies, although there are case reports of serious bleeding events, primarily in the elderly. | No new evidence. | No new information. | Experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There was no difference in rates of ulcer complications between celecoxib and nonselective NSAIDs in the subgroup of patients who took aspirin. Concomitant low-dose aspirin use increased the rate of endoscopic ulcers in both patients on celecoxib and those on nonselective NSAIDs. Rofecoxib plus low-dose aspirin or ibuprofen alone were associated with similar risks of endoscopic ulcers which were significantly higher than those for placebo (6 percent) or aspirin alone. Compared to nonuse of aspirin, concomitant aspirin use did not ameliorate the increased risk of vascular events associated with COX- 2 selective NSAIDs. | Etoricoxib was less likely to cause than uncomplicated GI complications than diclofenac in patient on low dose aspirin (Laine, 2007). | No new information. | One expert noted this seems to be an area of substantial interest as celecoxib is trying to keep market share, and there are at least some studies looking at endoscopic outcomes. One expert states “need to re-review aspirin in MEDAL. vs. aspirin in TARGET.” [Note: The MEDAL study was included in the original CER; In the original CER the TARGET study was included however the TARGET study indicated by the expert was not found in the original CER. | Conclusion is possibly out of date and this portion of the CER may need updating based on expert opinion.
Key Question 3: What are the comparative effects of coprescribing of H2-antagonists, misoprostol, or proton pump inhibitors (PPIs) on the gastrointestinal harms associated with NSAID use?
Consistent evidence found coprescribing of PPIs to be associated with the lowest rates of endoscopically detected duodenal ulcers relative to gastroprotective agents. Coprescribing of misoprostol is associated with similar rates of endoscopically detected gastric ulcers as coprescribing of PPIs. While misoprostol offers the advantage of being the only gastroprotective agent to reduce rates of perforation, obstruction, or bleeding, there is a high rate of withdrawals due to adverse GI symptoms. | Now new evidence. | No new information. | Three experts agreed the conclusion is still valid One expert stated that the results of the Vioxx Gastrointestinal Outcomes Research (VIGOR) study and Chan studies should be reviewed. | Conclusion is still valid and this portion of the CER does not need updating.
The risk of endoscopic duodenal ulcers for standard- dose H2 blockers was lower than placebo, similar to misoprostol, and higher than omeprazole. Standard dosages of H2 blockers were associated with no reduction of risk for gastric ulcers relative to placebo. Double (full) dose H2 blockers were associated with a lower risk of endoscopic gastric and duodenal ulcers relative to placebo. It is unknown how full-dose H2 blockers compare to other antiulcer medications. | No new evidence. | No new information. | Experts agree the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 4: What are the comparative benefits and harms of treating osteoarthritis with oral medications as compared with topical preparations? Topical preparations include: capsaicin, diclofenac, ibuprofen, ketoprofen, and salicylate.
Topical NSAIDs were similar to oral NSAIDs for pain relief in trials primarily of patients with osteoarthritis of the knee, with topical diclofenac (often with dimethyl sulphoxide [DMSO], a drug not approved for use in humans in the United States). Topical ibuprofen was superior to placebo in several trials. Consistent evidence from good-quality trials, systematic reviews, and observational studies found topical NSAIDs to be associated with increased local adverse events compared with oral NSAIDs. Total adverse events and withdrawal due to adverse events were similar. Data from one good-quality trial found topical NSAIDs superior to oral NSAIDs for GI events, including severe events, and changes in hemoglobin. Topical salicylates were no better than placebo in higher quality placebo-controlled trials. Compared to placebo, one additional patient achieved pain relief for every eight that used topical capsaicin in a good-quality meta-analysis, but capsaicin was associated with increased local adverse events and withdrawals due to adverse events. | This is further supported by a meta-analysis of topical diclofenac which suggested equivalent efficacy compared to oral diclofenac (Towheed, 2006). It was also shown superior to placebo in another study (Niethard, 2005). The updated search identified one RCT of topical ibuprofen that combined with a patient preference study found that advice to use topical ibuprofen versus oral ibuprofen had equivalent effects on pain as measured by the WOMAC (Western Ontario and McMaster Universities Osteoarthritis Index) scale. In this study, oral ibuprofen had more minor adverse events such as changes in serum creatinine (Underwood, 2008). | No new topical NSAIDs approved. | Experts agreed the conclusion is still valid. One expert noted: “a UK study of topical ibuprofen still had not been published last time I checked but was due any time; there may also be new studies of topical diclofenac. I thought I heard of a topical NSAID approved in the US but I am not positive about that”. [Note: The Underwood study summarized is the UK topical NSAID study referred to] | Conclusion is still valid and this portion of the CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? A systematic review and meta-analysis of tramadol or tramadol/acetaminophen use in osteoarthritis found modest benefits with the medication, with 1 in 8 discontinuing therapy because of side effects (Cepeda, 2007). A recent systematic review of randomized controlled trials did not find any evidence of efficacy for vitamin A, C, E or selenium for the treatment of any type of arthritis including osteoarthritis (Canter, 2007). One expert noted: I think one big question is whether the combination of naproxen + PPI is safer (from CV and GI risk standpoint) compared to celecoxib or a different nonselective, but I don’t know if anyone has gone so far as to conduct a head-to-head trial (though several experts are already recommending the naproxen + PPI combo). The topical NSAID area is likely to be one of the hotter ones. There isn’t exactly new evidence, but there has been varying interpretation of the NIH It hinges on whether a post-hoc subgroup analysis glucosamine trial. provides any reliable information. We thought it provided some information; others have completely dismissed it. Another comments: There is no mention of recent negative trials for glucosamine and chondroitin sulfate. Assume that other than topicals - non oral meds not included (ie no mention of acupuncture/hyaluronic acid.....) Another expert notes: I don’t see any statement about COX2 effectiveness compared with other NSAIDs- was this not a conclusion of the panel? The first conclusion just deals with moderately selective Cox2 inhibitors. There is large RCT that suggests etoricoxib and celicoxib are equal in efficacy and side effect profile (Bingham, 2007).

Legend: ADAPT: Alzheimer’s Disease Anti-inflammatory Prevention Trial; CHF: congestive heart failure, COPD: chronic obstructive pulmonary disease; COX-2: cyclooxygenase-2; CV: cardiovascular; CVD: cardiovascular disease; DMSO: dimethyl sulfoxide; GI: gastrointestinal; H2: histamine-2, HR: hazard ratio; MEDAL: Multinational Etoricoxib and Diclofenac Arthritis Long-term; OA: osteoarthritis; NSAID: non-steroidal anti-inflammatory drug; PPI: proton pump inhibitor; RA: rheumatoid arthritis; RCT: randomized controlled trial; TARGET: Therapeutic Arthritis Research and Gastrointestinal Event Trial; VIGOR: Vioxx Gastrointestinal Outcomes Research; WOMAC: Western Ontario and McMaster Universities Osteoarthritis Index

### References

Baraf HS, Fuentealba C, Greenwald M, et al. Gastrointestinal side effects of etoricoxib in patients with osteoarthritis: results of the Etoricoxib versus Diclofenac Sodium Gastrointestinal Tolerability and Effectiveness (EDGE) trial. J Rheumatol. Feb. 2007;34(2):408-420. [pmid: 17304660].
Bingham CO 3rd, Sebba AI, Rubin BR, et al. Efficacy and safety of etoricoxib 30 mg and celecoxib 200 mg in the treatment of osteoarthritis in two identically designed, randomized, placebo-controlled, non-inferiority studies. Rheumatology (Oxford). Mar. 2007;46(3):496-507. [pmid: 16936327].
Cannon CP, Curtis SP, FitzGerald GA, et al. Cardiovascular outcomes with etoricoxib and diclofenac in patients with osteoarthritis and rheumatoid arthritis in the Multinational Etoricoxib and Diclofenac Arthritis Long-term (MEDAL) programme: a randomised comparison. Lancet. Nov 18. 2006;368(9549):1771-1781. [pmid: 17113426].
Canter PH, Wider B, Ernst E. The antioxidant vitamins A, C, E and selenium in the treatment of arthritis: a systematic review of randomized clinical trials. Rheumatology (Oxford). Aug. 2007;46(8):1223-1233. [pmid: 17522095].
Cepeda MS, Camargo F, Zea C, Valencia L. Tramadol for osteoarthritis: a systematic review and metaanalysis. J Rheumatol. Mar. 2007;34(3):543-555. [pmid: 17343302].
Chan FK, Wong VW, Suen BY, et al. Combination of a cyclooxygenase-2 inhibitor and a proton-pump inhibitor for prevention of recurrent ulcer bleeding in patients at very high risk: a double-blind, randomised trial. Lancet. May 12. 2007;369(9573):1621-1626. [pmid: 17499604].
Clegg DO, Reda DJ, Harris CL, et al. Glucosamine, chondroitin sulfate, and the two in combination for painful knee osteoarthritis. N Engl J Med. Feb 23. 2006;354(8):795-808. [pmid: 16495392].
Herrero-Beaumont G, Ivorra JA, Del Carmen Trabado M, et al. Glucosamine sulfate in the treatment of knee osteoarthritis symptoms: a randomized, double-blind, placebo-controlled study using acetaminophen as a side comparator. Arthritis Rheum. Feb. 2007;56(2):555-567. [pmid: 17265490].
Laine L, Curtis SP, Cryer B, Kaur A, Cannon CP. Assessment of upper gastrointestinal safety of etoricoxib and diclofenac in patients with osteoarthritis and rheumatoid arthritis in the Multinational Etoricoxib and Diclofenac Arthritis Long-term (MEDAL) programme: a randomised comparison. Lancet. Feb 10. 2007;369(9560):465-473. [pmid: 17292766].
Niethard FU, Gold MS, Solomon GS, et al. Efficacy of topical diclofenac diethylamine gel in osteoarthritis of the knee. J Rheumatol. Dec. 2005;32(12):2384-2392. [pmid: 16331769].
Solomon DH, Glynn RJ, Rothman KJ, et al. Subgroup analyses to determine cardiovascular risk associated with nonsteroidal antiinflammatory drugs and coxibs in specific patient groups. Arthritis Rheum. Aug 15. 2008;59(8):1097-1104. [pmid: 18668605].
Solomon SD, Wittes J, Finn PV, et al. Cardiovascular risk of celecoxib in 6 randomized placebo-controlled trials: the cross trial safety analysis. Circulation. Apr 22. 2008;117(16):2104-2113. [pmid: 18378608].
Towheed TE. Pennsaid therapy for osteoarthritis of the knee: a systematic review and metaanalysis of randomized controlled trials. J Rheumatol. Mar. 2006;33(3):567-573. [pmid: 16511925].
Underwood M, Ashby D, Cross P, et al. Advice to use topical or oral ibuprofen for chronic knee pain in older people: randomised controlled trial and patient preference study. BMJ. Jan19. 2008;336(7636):138-142. [pmid: 18056743].

## CER 6. Efficacy and Comparative Effectiveness of Off-label Uses of Atypical Antipsychotics

For this CER, which was produced by the SCEPC, a full literature search was conducted for the years 2006–2008. The search identified 1,502 titles, of which 261 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of the 261 selected for further review, 38 were abstracted into an evidence table (Attachment II). The remaining articles were rejected because they had already been included in the earlier report or did not include a comparison of interest.

We consulted the original content expert and primary reviewer, 4 members of the TEP, and one additional expert for their assessments. Of these 6 individuals, four responded.

Table 2.5 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.5 CER 6. Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics: Are the conclusions still valid?

Conclusions From CER Executive Summary | SC EPC Literature Search | FDA/Health Canada | Expert Opinion | Conclusion from SC EPC
Conclusions From CER Executive Summary | SC EPC Literature Search | FDA/Health Canada | EPC Investigator, 3 TEP Members | Conclusion from SC EPC
Key Question 1: What are the leading off-label uses of atypical antipsychotics in the literature?
The most common off- label uses of atypical antipsychotics found in the literature were treatment of depression, obsessive-compulsive disorder, posttraumatic stress disorder, personality disorders, Tourette's syndrome, autism, and agitation in dementia. In October 2006, risperidone was approved for use in autism. | There are several new RCTs of atypicals for anorexia nervousa and bulimia (Mondraty, 2005; Bissada, 2008; Spettique, 2008). Court (2008) published a systematic review in Eating Disorders which included four RCTs. | No new information. | All experts agreed still valid. | Conclusion is still valid, but AHRQ may wish to expand scope to anorexia depending on sponsor and public interest.
Key Question 2: What does the evidence show regarding the effectiveness of atypical antipsychotics for off-label indications, such as depression? How do atypical antipsychotic medications compare with other drugs for treating off-label indications?
There is a small but statistically significant benefit for risperidone and aripiprazole on agitation and psychosis outcomes in dementia patients. The clinical benefits must be balanced against side effects and potential harms. | a) CATIE-AD found that olanzapine and risperidone improved NPI total score and BPRS (Brief Psychiatric Rating Scale) hostile suspiciousness factor. There were no significant differences between antipsychotics and placebo on cognition, function, care needs, or quality of life, except for worsened functioning with olanzapine (Sultzer, 2008). b) New RCT shows quetiapine 200 mg associated with significant improvements in PANNS-EC, CGI-C compared to placebo (Zhong, 2007). c) New meta-analysis shows effect sizes of atypical antipsychotics for behavioral problems in dementia are medium, and there are no statistically or clinically significant differences between them and placebo (Yury, 2007). d) Head to head RCT shows quetiapine and risperidone equally effective and well tolerated (Rainer, 2007). e) New systematic review on dementia symptoms shows olanzapine and risperidone effective compared with placebo. Short-term AEs similar to placebo. Risperidone had advantage over haldol in EPS. Evidence for other atypicals too limited to assess (Carson, 2006). f) New RCT found aripiprazole 10 mg/day was efficacious and safe for psychosis associated with AD, significantly improving psychotic symptoms, agitation, and clinical global impression (Mintzer, 2007). g) In another new RCT in nursing home residents with AD and psychosis, aripiprazole did not confer specific benefits for the treatment of psychotic symptoms; but psychological and behavioral symptoms, including agitation, anxiety, and depression, were improved with aripiprazole, with a low risk of AEs (Stein, 2008). h) A new RCT in elderly patients with organic brain disease (N= 15) showed no difference between risperidone and placebo, as measured by PANSS items (Naber, 2007). | In August 2008, FDA ordered a new boxed warning for all typical antipsychotics: Increased mortality in elderly patients with dementia-related psychosis. | Two experts agreed still valid. One expert cited additional trials that support efficacy in dementia patients: Streim, 2008 (aripiprazole); Mintzer, 2007 (aripiprazole); Sultzer, 2008 (olanzapine). Two experts did not comment. | Conclusion is possibly out of date and this portion of the CER may need updating. Although no experts felt the conclusion was out of date, we found new studies that reported olanzapine and quetiapine effective and two new meta-analyses.
For SRI-resistant patients with major depressive disorder, combination therapy with an atypical antipsychotic plus an SRI antidepressant is not more effective than an SRI alone at 8 weeks. | a) Aripiprazole approved by FDA for adjunctive tx in unipolar, non-psychotic depression after two new RCTs (Marcus, 2008; Berman, 2007). b) New RCT of risperidone augmentation showed higher odds of remitting (OR = 3.33) than placebo at 4 weeks (Keitner, 2008). [Original CER included only trials of 8 weeks or more.] c) New RCT shows olanzapine/fluoxetine combination effective at 8 weeks (Thase, 2007). d) Meta-analysis of 10 clinical trials finds patients on adjunct atypicals significantly more likely to experience remission or clinical response than those on adjunct placebo. No studies on aripiprazole or ziprasidone were included. The new meta-analysis used “remission rate” (% of patients improving a certain amount on HAM-D or MADRAS) as the outcome, while original CER used the continuous score. Also, they included one 4-week trial and one 6-week trial; the original CER excluded these as too short in duration. e) RCT of risperidone augmentation show a significant reduction in depression symptoms, substantial increase in remission and response, compared to augmentation with placebo at 6 weeks (Gharabawi, 2007). | In November 2007, aripiprazole was FDA approved as adjunctive treatment for major depressive disorder. | One expert did not know. One expert noted: a study in bipolar depression showing efficacy of olanzapine + fluoxetine over fluoxetine alone (Thase, 2007); 2 RCTs showing quetiapine monotherapy is superior to placebo in bipolar depression monotherapy (cited in Papakostas); and now FDA has approved apriprazole for acute bipolar depression. Two experts did not comment. | Conclusion is probably out of date and this portion of the CER may need updating based on the new FDA approval, plus new literature and expert opinion.
In patients with major depressive disorder with psychotic features, olanzapine and olanzapine plus fluoxetine were compared with placebo for 8 weeks in 2 trials. There was a benefit for | No contradictory evidence. | No new information. | Three experts agreed still valid; one of these experts suggested additional trials showing efficacy of olanzapine. One did not comment. | Conclusion is still valid and this portion of the CER does not need updating.
For bipolar depression, olanzapine and quetiapine were superior to placebo in one study for each drug, but data are conflicting in two other studies that compared atypical antipsychotics to conventional treatment. | Two new RCTs found aripriprazole not significantly more effective in bipolar depression than placebo at 8 weeks (Thase, 2008). | In October 2006 quetiapine was FDA approved for major depressive episodes associated with bipolar disorder. | One expert noted FDA approval of quetiapine for bipolar depression. Another expert mentioned a study in bipolar depression showing efficacy of olanzapine + fluoxetine over fluoxetine alone and two RCTs showing quetiapine monotherapy is more effective than placebo in bipolar depression. (These were included in the original CER). | Conclusion is still valid and this portion of the CER does not need updating. New RCTs did not show a benefit for aripiparazole, and the studies suggested by the expert were already included in the original CER.
We identified 12 trials of risperidone, olanzapine, and quetiapine used as augmentation therapy in patients w/OCD who were resistant to standard treatment (nine trials were sufficiently similar clinically to pool). Atypical antipsychotics have a clinically important benefit (measured by the Yale- Brown Obsessive- Compulsive Scale) when used as augmentation therapy for OCD patients who fail to adequately respond to SRI therapy. There were too few studies of olanzapine augmentation to permit separate pooling for this drug. | New head-to-head RCT showed both risperidone and olanzapine more effective than placebo, but no significant differences between the two drugs (Maina, 2008). A new RCT (Savas, 2008) showed that quetiapine is better than ziprasidone for augmentation therapy in OCD (Savas, 2008). | No new information. | Two experts agreed still valid. One of them noted the following new studies: Drug Neuropsych (15, 585–6) showed efficacy of SSRIs plus aripiprazole; a new study in Clinical Drug Investigation showed that quetiapine is better than ziprasidone for augmentation therapy in OCD (Savas, 2008); a new study in European Journal of Psychiatry showed that olazapine is equal to risperidone for augmentation therapy in OCD (Maina, 2008). Two experts did not comment. | Conclusion is possibly out of date and this portion of the CER may need updating due to publication of aripiprazole trial. The results from the two new head to head trials could be added to the pooling performed in the original CER.
We found four trials of risperidone and two trials of olanzapine of at least 6 weeks duration in patients with PTSD. There were three trials enrolling men with combat-related PTSD; these showed a benefit in sleep quality, depression, anxiety, and overall symptoms when risperidone or olanzapine was used to augment therapy with antidepressants or other psychotropic medication. There were three trials of olanzapine or risperidone as monotherapy for women with PTSD; the evidence was inconclusive regarding efficacy. | A new meta-analysis (Pae, 2008) including data from seven RCTs showed that atypicals may have a beneficial effect in the treatment of PTSD, as indicated by the changes from baseline in Clinician Administered PTSD Scale total scores. The symptom of 'intrusion' was mainly responsible for this significance. The original CER qualitatively summarized six of the trials separately for women and men. The Pae meta- analysis pools the male and female studies together. | No new information. | One expert noted the following: Int Clin Psychopharm Meta analysis of 7 RCTs (Pae, 2008) showed atypicals more effective than placebo, but only due to increase in intrusive symptoms. All experts agreed still valid. | Conclusion is still valid and this portion of the CER does not need updating.
We identified five trials of atypical antipsychotic medications as treatment for borderline personality disorder & one trial as treatment for schizotypal personality disorder. Three RCTs each w/no more than 60 subjects provide evidence that olanzapine is more effective than placebo & may be more effective than fluoxetine in treating borderline personality disorder. The benefit of adding olanzapine to dialectical therapy for borderline personality disorder was small. | An RCT of ziprasidone failed to show benefit in borderline personality disorder (Pascual, 2008). | No new information. | Our experts do not know this area well. | Conclusion is still valid and this portion of the CER does not need updating.
Risperidone was more effective than placebo for the treatment of schizotypal personality disorder in one small trial. | No new evidence. | No new information. | No expert comment on this issue. | Conclusion is still valid and this portion of the CER does not need updating.
Aripiprazole was more effective than placebo for the treatment of borderline personality in one small trial. | 18-month follow up of the original trial shows significant improvement at 18 months (Nickel, 2007). | No new information. | No expert comment on this issue. | Conclusion is still valid and this portion of the CER does not need updating.
We found four trials of risperidone and one of ziprasidone for treatment of Tourette's syndrome. Risperidone was more effective than placebo in one small trial, and it was at least as effective as pimozide or clonidine for 8 to 12 weeks of therapy in the three remaining trials. The one available study of ziprasidone showed variable effectiveness compared to placebo. | No new evidence. | No new information. | No expert comment on this issue. | Conclusion is still valid and this portion of the CER does not need updating.
Two trials support the superiority of risperidone over placebo in improving serious behavioral problems in children with autism. | Another trial showed that (non-autistic) children who respond to initial treatment with risperidone would benefit from continuous long-term treatment (Reyes, 2006). | No new information. | No expert comment on this issue. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 3: What subset of the population would potentially benefit from off-label uses?
Other than specific populations listed in the finding for Key Question 2, there was insufficient information to answer this question. Therefore, it is included as a topic for future research. | No new evidence. | No new information. | Experts do not know of new information. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 4: What are the potential adverse effects and/or complications involved with off-label prescribing of atypical antipsychotics?
Olanzapine patients are more likely to report weight gain than those taking placebo, other atypical antipsychotics, or conventional antipsychotics. | No new evidence. | No new information. | Three experts agreed still valid. The fourth feels there is weight gain with other atypicals and cites Schneider, 2006 (Catie-AD). However, that study was included in our original AE analyses and pooled results suggested olanzapine patients gain more weight. | Conclusion is still valid and this portion of the CER does not need updating.
In a recently published meta-analysis death occurred in 3.5 percent of dementia patients randomized to receive atypical antipsychotics vs. 2.3 percent of patients randomized to receive placebo. The difference in risk for death was small but statistically significant. Sensitivity analyses did not show evidence for differential risks for individual atypical antipsychotics. In another recently published meta- analysis of six trials of olanzapine in dementia patients, differences in mortality between olanzapine and risperidone were not statistically significant, nor were differences between olanzapine and conventional antipsychotics. | a) A new meta-analysis of six RCTs of risperidone regarding mortality in elderly dementia patients showed 4.0% mortality with risperidone versus 3.1% with placebo (relative risk 1.21, 95% CI 0.71–2.06) during tx or within 30 days or tx discontinuation (Haupt, 2006). b) Another study assessed short-term mortality in a population-based cohort of elderly people in British Columbia who were prescribed conventional or atypical antipsychotic medications. Within the first 180 days of use, 1822 patients (14.1%) in the conventional drug group died, compared with 2337 (9.6%) in the atypical drug group (mortality ratio 1.47, 95% CI 1.39–1.56). Multivariable adjustment resulted in a 180-day mortality ratio of 1.32 (1.23– 1.42) (Schneeweiss, 2007). c) Death rates for incident (N=16,634) and prevalent (N=9,831) users of various antipsychotics, carbamazepine, and sodium valproate age 65+ were compared. Haloperidol was consistently associated with increased risk of death compared with olanzapine (RR for incident users 2.26, 95% CI 2.08 – 2.47). Risperidone (RR 1.23, 95% CI: 1.07 – 1.40) was also associated with increased risk of death compared to olanzapine in incident users (Hollis, 2007). d) A new cohort study of medical records from the Tennessee Medicaid program found that current users of atypical antipsychotics had a rate of sudden cardiac death twice that of those who didn’t use such drugs and similar to those who took haloperidol or thiordazine. (Ray, 2009). | In August 2008, FDA ordered a new boxed warning for all typical antipsychotics: Increased mortality in elderly patients with dementia-related psychosis. | Three experts agreed still valid or did not know. The fourth noted that recent studies of atypicals vs conventionals show a higher risk possible with conventionals. | While the conclusion is still valid, the strength of evidence supporting the conclusion has increased and therefore this may possibly need updating.
In our pooled analysis of three RCTs of elderly patients with dementia, risperidone was associated with increased odds of cerebrovascular accident compared to placebo. This risk was equivalent to 1 additional stroke for every 31 patients treated in this patient population (i.e., number needed to harm of 31). The manufacturers of risperidone pooled four RCTs and found that cerebrovascular adverse events were twice as common in dementia patients treated with risperidone as in the placebo patients. In a separate industry- sponsored analysis of five RCTs of olanzapine in elderly dementia patients, the incidence of cerebrovascular adverse events was three times higher in olanzapine patients than in placebo patients. | a) Retrospective cohort study with N >40,000 used a logistic regression model to show that relative to those who received no antipsychotics, community dwelling elderly newly dispensed an atypical were 3.2 times more likely, and those who received a conventional antipsychotic were 3.8 more likely, to develop any serious event during the first 30 days (Rochon, 2008; Gill, 2007). b) Retrospective cohort study of VA data on patients age 65+ (N = 10,615) who began outpatient treatment with psyc meds following a dementia diagnosis showed that those taking antipsychotics had significantly higher mortality rates (22.6% to 29.1%) than patients taking non-antipsychotic meds (14.6%). Adjusted mortality risks for atypicals were similar to those for conventional antipsychotics. The proportions of patients taking antipsychotics who died from cerbrovascular, cardiovascular, or infectious causes were not higher than rates for those taking other psyc meds (Kales, 2007). | No new information. | Two experts agreed still valid. Two others did not comment. | Conclusion is still valid and this portion of the CER does not need updating.
We pooled three aripiprazole trials and four risperidone trials that reported extrapyramidal side effects (EPS) in elderly dementia patients. Both drugs were associated with an increase in EPS. | No new evidence. | No new information. | One expert agreed still valid. One other noted that EPS was reported with olanzapine (Schneider, 2006). That study was already included in our CER. Two others did not comment. | Conclusion is still valid and this portion of the CER does not need updating.
Ziprasidone was associated with an increase in EPS when compared to placebo in a pooled analysis of adults with depression, PTSD, or personality disorders. | No new evidence. | No new information. | Three experts agreed still valid. No comment from another. | Conclusion is still valid and this portion of the CER does not need updating.
Risperidone was associated with increased weight gain compared to placebo in our pooled analyses of three trials in children/adolescents. Odds were also higher for gastrointestinal problems, increased salivation, fatigue, EPS, and sedation among these young risperidone patients. | No new evidence. | No new information. | Two experts agreed still valid. Two others did not comment. | Conclusion is still valid and this portion of the CER does not need updating.
Compared to placebo, all a typicals were associated with sedation in multiple pooled analyses for all psychiatric conditions studied. | No new evidence. | No new information. | Two experts agreed still valid. Two others did not comment. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 5: What are the appropriate dose and time limit for off-label indications?
There was insufficient information to answer this question. Therefore, it is included as a topic for future research | No new evidence. | No new information. | One expert agreed still valid. Three others did not comment. | Conclusion is still valid and this portion of CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? | Glucose/Diabetes:Sacher (2008) reports a small RCT where olanzapine but not ziprasidone lead to a decrease in whole body insulin sensitivity in response to a hyperinsulinemic euglycemic challenge in healthy adults. Bayesian data-mining of FDA adverse events reporting system (DuMouchel, 2008) showed consistent and substantial differences between atypicals in reporting ratios re glycemic effects, especially life-threatening ones. Low association: ziprasidone, aripriprazole, and risperidone; medium association: quetiapine, and strong association: olanzapine. A VA retrospective cohort analysis (Duncan, 2007) showed that in patients without a random plasma glucose of >=160 mg/dl before medication exposure (n=1394), treatment with olanzapine, risperidone, or a typical antipsychotic was associated with an incidence of new diabetes-level hyperglycemia of 78.7 cases per 1,000 individuals exposed per year. Olanzapine was associated with a greater rate of developing at least one fasting glucose measurement of >=200 than risperidone (OR = 2.14). In a systematic review of 17 pharmacoepidemiologic studies (Ramaswamy, 2006) olanzapine, but not risperidone, was associated with significantly increased risk of new-onset diabetes. Of nine studies comparing relative risk of diabetes with olanzapine and risperidone, six demonstrated significantly greater risk with olanzapine. A retrospective study of schizophrenia patients at Mass General (Henderson, 2007) showed that the incidence of diabetes presenting as diabetic ketoacidosis was higher than in the general hospital population and differed across drugs (olanzapine, 0.8%, risperidone, 0.2%, no incidence with ziprasidone or quetiapine). A retrospective analysis of diabetes risk in elderly patients with dementia in seven olanzapine clinical trails (Micca, 2006) showed that risk of diabetes was not significantly associated with antipsyc treatment. Pituitary tumors: Sarfman (2006) analyzed the FDA AERS and found that risperidone had the highest adjusted reporting ratios for hyperprolactinemia, galactorrhea, and pituitary tumor among the antipsychotics, and one of the highest scores for all drugs in the database. Cholesterol: Using MediCal data, Olfson (2006) estimated the relative riskof developing hyperlipidemia after treatment with antipsychotics compared to no antipsychotic treatment. 12,133 incident cases of hyperlipidemia were matched to 72,140 control subjects. Compared with no antipsyc meds, tx with risperidone (OR 1.56, 95% CI 1.43– 1.64), quetiapine (OR 1.52, 95% CI1.40 – 1.65), olanzapine (OR 1.56, 95%CI 1.47 – 1.67) and ziprasidone(OR 1.40, CI 1.19 – 1.65) were associated with increased risk of hyperlipidemia, as were conventional antipsychotics (OR 1.26, 95% CI 1.14 –1.39). Muscle toxicity: Waring (2006) reviewed case notes from 64 consecutive patients admitted after olanzapine overdose. Serum creatine kinase was > 5 times the upper limit of normal in 17% of patients, and there was a dose-dependent relationship. No patients developed renal failure. New drug: Paliperidone-ER, first atypical with extended release formulation approved by FDA for schizophrenia (Lautneschlager, 2008; Yang, 2007; Owen, 2007; Howland, 2007). | | | Any new Comparative Effectiveness Review on atypical antipsychotics should assess glucose issues in the harms section, due to the number of recently published cohort analyses revealing glycemic effects.

Legend: AE: Adverse Event; BPRS: Brief Psychiatric Rating Scale; CGI: Clinical Global Impressions Scale; EPS: Extrapyramidal Side Effects; HAM-D: Hamilton Depression Score; MADRAS: Montgomery Asberg Depresson Rating Scale; NPI: Neuropsychiatric Inventory; PANNS: Positive and Negative Syndrom Scale; RCT: Randomized Controlled Trial; VA: Veterans Administration

### References

Bissada H, Tasca GA, Barber AM, Bradwejn J. Olanzapine in the treatment of low body weight and obsessive thinking in women with anorexia nervosa: a randomized, double-blind, placebo-controlled trial. Am J Psychiatry. Oct. 2008;165(10):1281-1288. [pmid: 18558642].
Carson S, McDonagh MS, Peterson K. A systematic review of the efficacy and safety of atypical antipsychotics in patients with psychological and behavioral symptoms of dementia. J Am Geriatr Soc. Feb. 2006;54(2):354-361. [pmid: 16460391].
DuMouchel W, Fram D, Yang X, et al. Antipsychotics, glycemic disorders, and life-threatening diabetic events: a Bayesian data-mining analysis of the FDA adverse event reporting system (1968–2004). Ann Clin Psychiatry. Jan-Mar. 2008;20(1):21-31. [pmid: 18297583].
Gill SS, Bronskill SE, Normand SL, et al. Antipsychotic drug use and mortality in older adults with dementia. Ann Intern Med. Jun 5. 2007;146(11):775-786. [pmid: 17548409].
Haupt M, Cruz-Jentoft A, Jeste D. Mortality in elderly dementia patients treated with risperidone. J Clin Psychopharmacol. Dec. 2006;26(6):566-570. [pmid: 17110812].
Henderson DC. Glucose metabolism in patients with schizophrenia treated with olanzapine or quetiapine: a frequently sampled intravenous glucose tolerance test and minimal model analysis. Journal of Clinical Psychiatry. 2007;65(5):801-802.
Hollis J, Grayson D, Forrester L, Brodaty H, Touyz S, Cumming R. Antipsychotic medication dispensing and risk of death in veterans and war widows 65 years and older. Am J Geriatr Psychiatry. Nov. 2007;15(11):932-941. [pmid: 17974865].
Howland RH. Paliperidone extended-release tablets: a new atypical antipsychotic. J Psychosoc Nurs Ment Health Serv. May. 2007;45(5):15-18.
Kales HC, Valenstein M, Kim HM, et al. Mortality risk in patients with dementia treated with antipsychotics versus other psychiatric medications. Am J Psychiatry. Oct. 2007. 164(10):1568-1576. quiz 1623. [pmid: 17898349].
Keitner GI, Garlow SJ, Ryan CE, et al. A randomized, placebo-controlled trial of risperidone augmentation for patients with difficult-to-treat unipolar, non-psychotic major depression. J Psychiatr Res. Jan. 2009;43(3):205-214. [pmid: 18586273].
Mahmoud RA, Pandina GJ, Turkoz I, et al. Risperidone for treatment-refractory major depressive disorder: a randomized trial. Ann Intern Med. 2007;147(9):593-602. [pmid: 17975181].
Maina G, Pessina E, Albert U, Bogetto F. 8-week, single-blind, randomized trial comparing risperidone versus olanzapine augmentation of serotonin reuptake inhibitors in treatment-resistant obsessive-compulsive disorder. Eur Neuropsychopharmacol. May. 2008;18(5):364-372. [pmid: 18280710].
Micca JL, Hoffmann VP, Lipkovich I, Ahl J, Baker RW, Hardy TA. Retrospective analysis of diabetes risk in elderly patients with dementia in olanzapine clinical trials. Am J Geriatr Psychiatry. Jan. 2006;14(1):62-70. [pmid: 16407583].
Mintzer JE, Tune LE, Breder CD, et al. Aripiprazole for the treatment of psychoses in institutionalized patients with Alzheimer dementia: a multicenter, randomized, double-blind, placebo-controlled assessment of three fixed doses. Am J Geriatr Psychiatry. Nov. 2007;15(11):918-931. [pmid: 17974864].
Mondraty N, Birmingham CL, Touyz S, Sundakov V, Chapman L, Beumont P. Randomized controlled trial of olanzapine in the treatment of cognitions in anorexia nervosa. Australas Psychiatry. Mar. 2005;13(1):72-75. [pmid: 15777417].
Naber D, Greenspan A, Schreiner A. Efficacy and safety of risperidone in the treatment of elderly patients suffering from organic brain disease (organic brain syndrome): results from a double-blind, randomized, placebo-controlled clinical trial. Psychopharmacology (Berl). May. 2007;191(4):1027-1029. [pmid: 17333131].
Nickel MK, Loew TH, Pedrosa Gil F. Aripiprazole in treatment of borderline patients, part II: an 18-month follow-up. Psychopharmacology (Berl). May. 2007;191(4):1023-1026. [pmid: 17318503].
Olfson M, Marcus SC, Corey-Lisle P, Tuomari AV, Hines P, L'Italien GJ. Hyperlipidemia following treatment with antipsychotic medications. Am J Psychiatry. Oct. 2006;163(10):1821-1825. [pmid: 17012695].
Owen RT. Extended-release paliperidone: efficacy, safety and tolerability profile of a new atypical antipsychotic. Drugs Today (Barc). Apr. 2007;43(4):249-258. [pmid: 17460786].
Pae CU, Lim HK, Peindl K, et al. The atypical antipsychotics olanzapine and risperidone in the treatment of posttraumatic stress disorder: a meta-analysis of randomized, double-blind, placebo-controlled clinical trials. Int Clin Psychopharmacol. Jan. 2008;23(1):1-8. [pmid: 18090502].
Papakostas GI, Shelton RC, Smith J, Fava M. Augmentation of antidepressants with atypical antipsychotic medications for treatment-resistant major depressive disorder: a meta-analysis. J Clin Psychiatry. Jun. 2007;68(6):826-831. [pmid: 17592905].
Pascual JC, Soler J, Puigdemont D, et al. Ziprasidone in the treatment of borderline personality disorder: a double-blind, placebo-controlled, randomized study. J Clin Psychiatry. Apr. 2008;69(4):603-608. [pmid: 18251623].
Philip NS, Carpenter LL, Tyrka AR, Price LH. Augmentation of antidepressants with atypical antipsychotics: a review of the current literature. J Psychiatr Pract. Jan. 2008;14(1):34-44. [pmid: 18212601].
Rainer M, Haushofer M, Pfolz H, Struhal C, Wick W. Quetiapine versus risperidone in elderly patients with behavioural and psychological symptoms of dementia: efficacy, safety and cognitive function. Eur Psychiatry. Sep. 2007;22(6):395-403. [pmid: 17482432].
Ramaswamy K, Masand PS, Nasrallah HA. Do certain atypical antipsychotics increase the risk of diabetes? A critical review of 17 pharmacoepidemiologic studies. Ann Clin Psychiatry. Jul-Sep. 2006;18(3):183-194. [pmid: 16923657].
Ray WA, Chung CP, Murray KT, Hall K, Stein CM. Atypical antipsychotic drugs and the risk of sudden cardiac death. N Engl J Med. Jan 15. 2009;360(3):225-235. [pmid: 19144938].
Reyes M, Buitelaar J, Toren P, Augustyns I, Eerdekens M. A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry. Mar. 2006;163(3):402-410. [pmid: 16513860].
Rochon PA, Normand SL, Gomes T, et al. Antipsychotic therapy and short-term serious events in older adults with dementia. Arch Intern Med. May 26. 2008;168(10):1090-1096. [pmid: 18504337].
Sacher J, Mossaheb N, Spindelegger C, et al. Effects of olanzapine and ziprasidone on glucose tolerance in healthy volunteers. Neuropsychopharmacology. Jun. 2008;33(7):1633-1641. [pmid: 17712347].
Savas HA, Yumru M, Ozen ME. Quetiapine and ziprasidone as adjuncts in treatment-resistant obsessive-compulsive disorder: a retrospective comparative study. Clin Drug Investig. 2008;28(7):439-442.
Schneeweiss S, Setoguchi S, Brookhart A, Dormuth C, Wang PS. Risk of death associated with the use of conventional versus atypical antipsychotic drugs among elderly patients. CMAJ. Feb 27. 2007;176(5):627-632. [pmid: 17325327].
Spettigue W, Buchholz A, Henderson K, et al. Evaluation of the efficacy and safety of olanzapine as an adjunctive treatment for anorexia nervosa in adolescent females: a randomized, double-blind, placebo-controlled trial. BMC Pediatr. 2008;8:4. [pmid: 18234120].
Streim JE. A randomized, double-blind placebo-controlled study of aripiprazole for the treatment of psychosis in nursing home patients with Alzheimer disease. Am J Geriatr Psychiatry. Jul. 2008;16(7):537-50. [pmid: 18591574].
Sultzer DL, Davis SM, Tariot PN, et al. Clinical symptom responses to atypical antipsychotic medications in Alzheimer's disease: phase 1 outcomes from the CATIE-AD effectiveness trial. Am J Psychiatry. Jul. 2008;165(7):844-854. [pmid: 18519523].
Thase ME, Jonas A, Khan A, et al. Aripiprazole monotherapy in nonpsychotic bipolar I depression: results of 2 randomized, placebo-controlled studies. J Clin Psychopharmacol. Feb. 2008;28(1):13-20. [pmid: 18204335].
Thase ME, Macfadden W, Weisler RH, et al. "Erratum re: Article 'Efficacy of Quetiapine Monotherapy in Bipolar I and II Depression: A Double-blind, Placebo-controlled Stody (The BOLDER II Study)'". J Clin Psychopharmacol. 2007;27(1):51.
Yang LP, Plosker GL. Paliperidone extended release. CNS Drugs. 2007;21(5):417-425. discussion 426–417. [pmid: 17447829].
Yury CA, Fisher JE. Meta-analysis of the effectiveness of atypical antipsychotics for the treatment of behavioural problems in persons with dementia. Psychother Psychosom. 2007;76(4):213-218. [pmid: 17570959].
Zhong KX, Tariot PN, Mintzer J, Minkwitz MC, Devine NA. Quetiapine to treat agitation in dementia: a randomized, double-blind, placebo-controlled study. Curr Alzheimer Res. Feb. 2007;4(1):81-93. [pmid: 17316169].

## CER 7. Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression

For this assessment, a full literature search was conducted for the years 2000–2008 using the PubMed and PsychInfo search platforms. The search identified 2,836 titles, of which 376 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of those selected for further review, 31 were abstracted into an evidence table (Attachment II). The remaining articles were rejected because they had already been included in the earlier report or did not include a comparison of interest.

We consulted the project lead and three additional subject matter experts for their assessments. Of these four individuals, three responded.

Table 2.6 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

As this report was being prepared, a new meta-analysis appeared that assessed the comparative effectiveness of 12 second-generation antidepressants (Cipriani et al., 2009). This analysis included data from 117 RCTs and used indirect comparison methods to conclude that escitalopram and sertraline are superior to the other drugs in both efficacy and acceptability. However, in a letter of response, the authors of the AHRQ CER point out that the indirect methods used portray a degree of precision in the results that is not present on direct comparisons. Our assessment of this new meta-analysis agrees with theirs: we do not judge this new analysis as indicating necessarily that CER #7 is out of date.

Table 2.6 CER 7. Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SC EPC
Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | EPC Investigator 1 TEP Member, 1 Other Expert | Conclusion from SC EPC
Key Question 1: 1a. For adults with major depressive disorder (MDD), dysthymia, or subsyndromal depressive disorders, do commonly used medications for depression differ in efficacy or effectiveness in treating depressive symptoms?
The relative risk (RR) of response was significantly greater for escitalopram than for citalopram. | Two placebo-controlled trials and a head-to- head superiority study show escitalopram was numerically better than citalopram in reducing Montgomery-Åsberg Depression Rating Scale (MADRS). Meta-analysis of 5 clinical trials (3 placebo-controlled trials, 1 head-to-head superiority study, and 1 long- term non-inferiority study) showed statistically significant differences in favor of escitalopram in terms of reducing MADRS and increasing response (Clancon, 2007). | No new information. | Two experts agreed the conclusion is still valid. One expert noted that s/he does not know. | Conclusion is still valid and this portion of the CER does not need updating.
Fluoxetine vs. paroxetine: We did not find any statistically significant differences in effect sizes on the Hamilton Rating Scale for Depression (HAM-D) or response rates between fluoxetine and paroxetine. Paroxetine led to a higher rate of responders than fluoxetine. | An analysis of 12 randomized controlled trials (RCTs) of patients with depressive disorder, comparing paroxetine and fluoxetine, found inconsistent results across efficacy outcomes (Katzman, 2007). | No new information. | Three experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Fluoxetine vs. sertraline: Patients on sertraline had an additional, statistically nonsignificant treatment effect of a 0.75- point reduction (95-percent CI, −0.45–1.95) on the HAM-D scale compared with patients on fluoxetine. The relative risk of response was significantly greater for sertraline than for fluoxetine. | No new evidence. | No new information. | Three experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Fluoxetine vs. venlafaxine: Patients on venlafaxine had an additional, statistically nonsignificant treatment effect of a 1.31- point reduction on the HAM-D scale compared with patients on fluoxetine. The relative risk of response was significantly greater for venlafaxine than for fluoxetine. | A direct comparison of venlafaxine vs. fluoxetine among patients with major depressive disorder, followed up for 1 year, found no significant difference in time to rehospitalization (Lin, 2008). A meta-analysis of 34 RCTs, comparing venlafaxine to fluoxetine, found venlafaxine is statistically superior to fluoxetine (Nemeroff, 2008). | No new information. | One expert agreed the conclusion is still valid. One expert said the conclusion is no longer valid based on 2 new head-to-head trials of venlafaxine vs. fluoxetine: the pooled estimate would most likely lose statistical significance. One expert said s/he does not know - but that this finding needs to be reviewed as there have been additional RCTs in venlafaxine (unsure of comparator). | Conclusion is possibly out of date and this portion of the CER may need updating. Although we found only one new conflicting RCT, methods and inclusion criteria of new meta-analysis (Nemeroff, 2008) should be reviewed.
Findings from indirect comparisons yielded no statistically significant differences in response rates. The precision of some of these estimates was low, leading to inconclusive results with wide confidence intervals. | Indirect comparison of escitalopram vs. venlafaxine XR, using 10 placebo-controlled studies, and two direct comparison studies found escitalopram was non-inferior to venlafaxine XR (indirect comparison: mean −0.02, 95% CI −0.16 to infinity; direct comparison: mean: 0.23, 95% CI: −0.01 to infinity). The results were consistent after controlling age, gender repartition and severity at baseline (Eckert, 2006). | No new information. | Three experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Eighteen studies indicated no statistical differences in efficacy with respect to health-related quality of life (HRQOL). | No new evidence. | No new information. | Three experts agreed the conclusion is still valid. One expert said s/he did not know. “I am unaware of important new direct evidence but there are new data on adverse effects including GI bleeding, osteoporosis. New data on sexual dysfunction, new data on effect on pain which could be incorporated into models to estimate effects on health-related quality of life.” | Conclusion is still valid and this portion of the CER does not need updating. New data on adverse events(suggested by one expert) is covered in key question4.
Seven studies funded by the maker of mirtazapine reported that mirtazapine had a significantly faster onset of action than citalopram, fluoxetine, paroxetine, and sertraline. | No new evidence. | No new information. | Two experts agreed the conclusion is still valid. One expert said s/he does not know. | Conclusion is still valid and this portion of the CER does not need updating.
We identified no head-to-head trials for dysthymia. In placebo-controlled trials, significant differences in population characteristics make the evidence insufficient to identify differences between treatments. | No new evidence. | No new information. | One expert said the conclusion is still valid. One expert said s/he does not know- “Evidence is sparse. Need periodic lit searches to identify any new study.” One expert said s/he does not know. | Conclusion is still valid and this portion of the CER does not need updating.
The only head-to-head evidence for treating patients with subsyndromal depression came from a nonrandomized, open-label trial comparing citalopram with sertraline. This study did not detect any differences in efficacy. Findings from two placebo- controlled trials were insufficient to draw any conclusions about the comparative efficacy and effectiveness. | No new evidence. | No new information. | Two experts agreed the conclusion is still valid. One expert said s/he does not know. | Conclusion is still valid and this portion of the CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? A pooled analysis of 9 RCTs, comparing duloxetine with placebo for 8–9 weeks, found duloxetine produced significantly greater baseline-to-endpoint mean change than placebo in HAM-D17 total score, Maier and retardation subscales, and the Clinical Global Impressions-Severity of Illness scale in mild (HAM-D17: < or =19; n=682), moderate (HAM-D17: between 19 and 25, n=1099), or severe (HAM-D17: > or =25; n=446) groups. Effective sizes were largest in the most severely depressed patients (Shelton, 2007). An analysis of 62 RCTs of patients with depressive disorder, comparing paroxetine vs. placebo or other antidepressants (amisulpride, amitriptyline, bupropion, clomipramine, doxepin, fluvoxamine, fluoxetine, imipramine, lofepramine, mianserin, mirtazapine, moclobemide, maprotiline, nefazodone, nortriptyline, sertraline, tianeptine, venlafaxine), found paroxetine yielded consistently and significantly better remission (rate difference [RD]: 10%, 95% CI 6 to 14), clinical response (RD: 17%, 95% CI 7 to 27), and symptom reduction (effect size: 0.2, 95% CI 0.1 to0.3) than placebo. No consistent and significant difference was observed between paroxetine and other antidepressants (Katzman, 2007). A prospective, 24-week open label study of 170 patients with major depressive disorder, comparing venlafaxine vs. paroxetine, found venlafaxine was comparable with paroxetine on response rate and remission, whereas paroxetine produced significantly higher remission rates at weeks 4, 8, 16, 20, 24 when remission was defined as HAM-D =5. Conclusion: Venlafaxine treatment was similar to paroxetine according to the typical efficacy measures. However, the authors feel that paroxetine might be superior to venlafaxine if the stricter remission criterion is used (Wu, 2007). A meta-analysis of 34 RCTs, comparing venlafaxine and selective serotonin reuptake inhibitors SSRIs (fluoxetine, sertraline, paroxetine, fluvoxamine, and citalopram), found venlafaxine had higher intention to treat (ITT) remission rate than the SSRIs as a group (the overall difference is 5.9%, 95% CI 0.038 to 0.081; p<0.001). The number needed to treat (NNT) to benefit is 17 (95% CI 12–26). The difference vs. fluoxetine was significant (6.6%, 95% CI 0.030 to 0.095); smaller difference vs. paroxetine, sertraline, and citalopram were not significant. Venlafaxine therapy is statistically superior to SSRI as a class, but only to fluoxetine individually. The clinical significance of the modest advantage seems limited to the broad grouping of major depressive disorder(Nemeroff, 2008).
1b. If a patient has responded to one agent in the past, is that agent better than current alternatives at treating depressive symptoms?
We did not find any efficacy evidence regarding this question. | No new evidence. | No new information. | One expert said the conclusion is still valid. One expert responded “there is no new information to my knowledge.” | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 2: 2a. For adults with a depressive syndrome, do antidepressants differ in their efficacy or effectiveness for maintaining response or remission (i.e., preventing relapse or recurrence)?
Three head-to-head RCTs suggest that no substantial differences exist between fluoxetine and sertraline, fluvoxamine and sertraline, and trazodone and venlafaxine, regarding relapse. Twenty-one placebo- controlled trials support the general efficacy and effectiveness of most second- generation antidepressants for preventing relapse or recurrence. No evidence exists for duloxetine. | A review of 5 placebo-controlled acute- phase studies found most of the relapse rate during new-generation antidepressant continuation treatment may be due to relapse in patients who were not true drug responders (Zimmerman, 2007). A meta-analysis of 1,833 outpatients with major depressive disorder found the HAMD- sub-1-sub-7 remission rate was 40.3% for duloxetine, 38.3% for 2 SSRIs (paroxetine or fluoxetine), and 28.4% for placebo. Active treatments were superior to placebo. The difference between duloxetine and SSRIs was not statistically significant. Duloxetine therapy was significant more effective than therapy with the 2 SSRIs for patients with more severe depression, with remission rates of 35.9% vs. 28.6% (P=0.046) (Thase, 2007). An update of the original report, using four head-to-head trials and 23 placebo- controlled trials from 1980–2007, did not find statistically difference in relapse or recurrence prevention between duloxetine and paroxetine, fluoxetine and sertraline, and trazodone and venlafaxine. Compared with placebo, the class of second-generation antidepressants had a relatively large effect size that persists over time. The number of patients needed to treat is 5 (95% CI: 4–6) (Hansen, 2008). | No new information. | Two experts agreed the conclusion is still valid. One expert said s/he does not know. | Conclusion is possibly out of date and this portion of the CER may need updating to include evidence for duloxetine.
2b. For adults receiving antidepressant treatment for a depressive syndrome that either has not responded (acute phase) or has relapsed (continuation phase) or recurred (maintenance phase), do alternative antidepressants differ in their efficacy or effectiveness?
One head-to-head efficacy study and two effectiveness studies provide conflicting evidence on differences among second- generation antidepressants in treatment- resistant depression. The efficacy study suggests that venlafaxine is modestly more effective than paroxetine. A good-quality effectiveness study suggests that no substantial differences exist among bupropion SR, sertraline, and venlafaxine XR, but a fair-quality effectiveness study suggests that venlafaxine is modestly more effective than citalopram, fluoxetine, mirtazapine, paroxetine, and sertraline. | A review of 5 randomized comparative studies (3 RCTs and 2 randomized open label studies) and 9 non-randomized non- comparative studies (2 switch studies, 5 open label switch studies, 1 post-hoc analysis, and 1 open case study) of >5,000 patients with treatment resistant depression supports the use of venlafaxine as a common switch agent following initial antidepressant failure (Dunner, 2007). An 8-week double-blind, placebo controlled trial of elderly patients with recurrent major depressive disorder comparing duloxetine vs. placebo, found duloxetine significantly improved cognition, depression and some pain measures. Hamilton depression scale response (37.3% vs. 18.6%) and remission (27.4% vs. 14.7%) rates at endpoint were significantly higher for duloxetine than placebo (Raskin, 2007). | No new information. | One expert agreed the conclusion is still valid. Two experts said they do not know. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 3: 3a. Do medications differ in their efficacy and effectiveness in treating the depressive episode?
Antidepressant medications do not differ substantially in antidepressive efficacy for patients with MDD and anxiety symptoms. | A prospective cohort study of 6,719 adult patients with depressive syndrome and associated with anxiety symptoms, treated with venlafaxine XR for 24 weeks, found venlafaxine XR was associated with significant decrease in the scores in the HAM-D depression rating and HAM-A anxiety rating (Benassar, 2006). | No new information. | Three experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
3b. Do medications differ in their efficacy and effectiveness in treating the accompanying symptoms?
One fair-quality head-to-head trial reported no statistically significant difference between fluoxetine and sertraline for treating depression in patients with psychomotor retardation. The same study found that sertraline was more efficacious than fluoxetine for treating depression in patients with psychomotor agitation. | A meta-analysis of 44 placebo-controlled trials of patients with Parkinson’s disease and depression found a modestly positive and significant effect size result with SSRIs on motor function (d=0.34, p<0.05) (Frisina, 2005). | No new information. | Two experts agreed the conclusion is still valid. One expert said s/he does not know. | Conclusion is possibly out of date and this portion of the CER may need to be updated to add points regarding treatment of Parkinson’s symptoms and pain (see below).
Are there new data that could inform the key questions that might not be addressed in the conclusions? An analysis of 10 double blind head-to-head trials of patients with major depressive disorder found bupropion and the SSRIs appear to be equally effective in treating insomnia in depression (Papakostas, 2007). A pooled analysis of 9 RCTs, comparing duloxetine with placebo for 8–9 weeks, found mildly (HAM-D17: < or =19; n=682) and severely (HAM-D17: > or =25; n=446) depressed patients with duloxetine exhibited significant reduction in Visual Analog Scale overall pain severity. (Shelton, 2007) An 8-week double-blind, placebo controlled trial of elderly patients with recurrent major depressive disorder, comparing duloxetine vs. placebo, found duloxetine significantly improved Visual Analogue Scale scores for back pain and time in pain while awake vs. placebo (Raskin, 2007).
Key Question 4: For adults with a depressive syndrome, do commonly used antidepressants differ in safety, adverse events, or adherence? Adverse effects of interest include but are not limited to nausea, diarrhea, headache, tremor, daytime sedation, decreased libido, failure to achieve orgasm, nervousness, insomnia, and more severe events including suicide.
Constipation, diarrhea, dizziness, headache, insomnia, nausea, and somnolence were commonly and consistently reported adverse events. On average, 61 percent of patients in efficacy trials experienced at least one adverse event. Nausea and vomiting were found to be the most common reasons for discontinuation in efficacy studies. Overall, second-generation antidepressants have similar adverse events profiles. | An update of the original report, using four head-to-head trials and 23 placebo- controlled trials from 1980–2007, found the most common adverse event due to treatment of second generation antidepressants (including duloxetine, paroxetine, fluoxetine, sertraline, trazodone and venlafaxine) in continuation- and maintenance-phase studies was headache, followed by nausea (weighted mean incidence=15.5% and 7.4%, respectively). Compared with the incidence of adverse events in acute-phase studies, the relative incidence during long-term treatment was slightly lower (Hansen, 2008). In the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) trial, among 2,876 patients with major depression, ratings of side effect frequency, intensity, and burden, as well as the number of serious adverse events, were significantly greater in the anxious depression group than those with nonanxious depression (Fava, 2008). A retrospective cohort study of elderly patients prescribed SSRIs found the risk of poisoning during SSRI use was higher than nonuse. The adjusted hazard ratio (95% CI) of poisoning was higher during SSRI use vs. nonuse (1.16 [1.07 to 1.25]) and varied between SSRI agents from 0.93 (0.74 to 1.16) for fluoxetine to 1.45 (1.23 to 1.71) for fluvoxamine (Rahme, 2008). Analyses of RCTs, comparing escitalopram with placebo or other antidepressants (citalopram, fluoxetine, paroxetine, sertraline, venlafaxine), found nausea was the only AE with an incidence greater than or equal to 10% and 5 percentage points greater than with placebo during short-term treatment. In general, AEs of escitalopram were mild to moderate in severity (Baldwin, 2007). | No new information. | Three experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Discontinuation syndromes (e.g., headache, dizziness, nausea) occurred in 0 to 86 percent of patients. Paroxetine and venlafaxine had the highest incidence of this problem, and fluoxetine the lowest incidence. | Analyses of RCTs, comparing escitalopram with placebo or other antidepressants (citalopram, fluoxetine, paroxetine, sertraline, venlafaxine), found, compared with paroxetine, escitalopram resulted in significantly fewer discontinuation symptoms (average increase in Discontinuation Emergent Signs and Symptoms Scale of 1.6 vs. 3.9, p<0.01) (Baldwin, 2007). | No new information. | Three experts agreed the conclusion is still valid. | Conclusion is possibly out of date and this portion may need updating. New analyses should be reviewed for methods, inclusion criteria, funding source.
Overall discontinuation rates did not differ significantly between SSRIs as a class and bupropion, mirtazapine, nefazodone, trazodone, and venlafaxine. In the case of venlafaxine compared with SSRIs, higher discontinuation rates because of adverse events appear to be balanced by lower discontinuation rates because of lack of efficacy. | An analysis of the Medical Expenditure Panel Survey for 1996–2001 found 42.4% of patients discontinued antidepressant therapy during the first 30 days. 27.6% of the patients continued antidepressant treatment for more than 90 days. Antidepressant discontinuation during the first 30 days was more common among Hispanics (53.8%) than non-Hispanics (43.7%), patients with few than 12 years of education than those with 12 or more years of education (Olfson, 2006). A prospective cohort study of 6,719 adult patients with depressive syndrome and associated with anxiety symptoms, treated with venlafaxine XR for 24 weeks, found 81.8% of patients completed 24 weeks of treatment (Roca, 2006). An analysis of 62 RCTs found controlled- release paroxetine had significantly fewer dropouts due to adverse events than immediate-release paroxetine (RD: 5%, 95% CI 0.1 to 11). No other difference found between paroxetine and other antidepressants (amisulpride, amitriptyline, bupropion, clomipramine, doxepin, fluvoxamine, fluoxetine, imipramine, lofepramine, mianserin, mirtazapine, moclobemide, maprotiline, nefazodone, nortriptyline, sertraline, tianeptine, venlafaxine) (Katzman, 2007). Analyses of RCTs, comparing escitalopram with placebo or other antidepressants (citalopram, fluoxetine, paroxetine, sertraline, venlafaxine), the 8 week withdrawal rate due to AEs was higher with escitalopram than with placebo (7.3% vs. 2.8%, p<0.001) but lower than with paroxetine (6.6% vs. 9.0%; p<0.01) or venlafaxine (6.1% vs. 13.2%, p<0.01) (Baldwin, 2007). | No new information. | Three experts agreed the conclusion is still valid. | Conclusion is possibly out of date and this portion may need updating based on new analysis showing lower drop out rate with escitalopram.
Bupropion is associated with a lower incidence of sexual dysfunction than fluoxetine, paroxetine, and sertraline. In head-to-head trials, paroxetine consistently had higher rates of sexual dysfunction than comparators (fluoxetine, fluvoxamine, nefazodone, and sertraline). | Analyses of RCTs, comparing escitalopram with placebo or other antidepressants (citalopram, fluoxetine, paroxetine, sertraline, venlafaxine), found AEs related to sexual dysfunction were similarly frequent with escitalopram and citalopram, but were higher with paroxetine (Baldwin, 2007). | No new information. | Three experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
The existing evidence on the comparative risk for rare but severe adverse events, such as suicidality, seizures, cardiovascular events (i.e., elevated systolic and diastolic blood pressure and elevated pulse/heart rate), hyponatremia, hepatotoxicity, and serotonin syndrome, is insufficient to draw firm conclusions. | A matched case-control study with Medicaid beneficiaries did not find antidepressant drugs are statistically associated with suicide attempts (OR: 1.10 95% CI 0.86–1.39) or suicide deaths (OR 0.90, 95% CI: 0.52–1.55) in adults. However, in children and adolescents, antidepressant drugs were significantly associated with suicide attempts (OR, 1.52, 95% 1.12–2.07) and suicide deaths (OR, 15.62; 95% CI, 1.65-infinity) (Olfson, 2006). A comparison of before and during 12 weeks of antidepressant treatment in 437 elderly patients with major depression found 7.8% with emergent suicidality, 12.6% with persistent suicidality, and 15.6% with resolved suicidality. Rates of emergent suicidality didn’t differ significantly between paroxetine-and nortriptyline-treated patients (Szanto, 2007). A observational cohort study in Denmark found patients who continued treatment with antidepressants had a decreased rate of suicide compared to those who purchased antidepressant once (rate ratio: 0.31, 95% CI: 0.26–0.36). The rate of suicide decreased consistently with the number of prescriptions (Sondergard, 2007). A retrospective cohort study with 219,099 UK patients found venlafaxine was associated with an increased risk of attempted suicide, compared to citalopram, fluoxetine and dothiepin. For completed suicides, unadjusted and adjusted hazard ratio for venlafaxine compared with citalopram were 2.44 (95% 1.12 to 5.31) and 1.70 (95% CI 0.76–3.80), for venlafaxine compared with fluoxetine were 2.85 (95% CI 1.37 to 5.94) and 1.63 (95% CI 0.74 to 3.59) (Rubino, 2007). A retrospective cohort study of elderly patients prescribed SSRIs found the risk of suicide death was not higher during periods of SSRI use vs. nonuse. The adjusted risk of suicide death was not higher during SSRI use vs. nonuse (hazard ratio (95% CI)): any SSRI=0.64 (0.38 to 1.07), paroxetine=0.71 (0.37 to 1.35), citalopram=1.16 (0.59 to 2.25), and sertraline=0.38 (0.16 to 0.93) (Rahme, 2008). An evaluation of 12 placebo controlled trials of MDD patients, comparing duloxetine vs. placebo didn’t find significant difference in the incidence of suicide-related events (Acharya, 2006). Analyses of RCTs, comparing escitalopram with placebo or other antidepressants (citalopram, fluoxetine, paroxetine, sertraline, venlafaxine), did not find significant differences between escitalopram and placebo in incidence of suicidal behavior, measured by self-harm and suicidal thoughts. The incidence of cardiovascular events with escitalopram was similar to that with placebo (Baldwin, 2007). An open-label study of 62 patients aged 60+ with major depressive disorder, treated with venlafaxine XR for 12 weeks, found 24% (95% CI 7.3% to 40.7%) of initially normotensive participants and 54% (95% CI 34.3% to 74%) of those with preexisting hypertension experienced an increase in blood pressure. 29% (95% CI 14.6% to 43.4%) developed orthostatic hypotension. 2 experienced a clinically significant increase in QTc interval. 1 participant reported new- onset mild dizziness, 4 reported new-onset tachycardia or palpitation. Overall, 17 unique participants (28.8%, 95% CI 17.3% to 40.4%) experienced a new-onset cardiovascular problem. Systematic monitoring of cardiovascular parameters during treatment with venlafaxine-XR should be strongly recommended, especially in the elderly (Johnson, 2006). | 07/2006 SSRIs Active FDA Safety Alert “increased risk for Persistent Pulmonary Hypertension in babies born to mothers who took selective serotonin reuptake inhibitors (SSRIs) and increased risk for Serotonin Syndrome in patients who use SSRIs and triptans together”. 07/2006 Serotonin- norepinephrine reuptake inhibitors (SNRIs) Active FDA Safety Alert “increased risk for Serotonin Syndrome in patients who use SSRIs and triptans together”. | Three experts agreed the conclusion is still valid. | Conclusion is possibly out of date and this portion of the CER may need updating based on new U.K. cohort study of over 200,000 patients.
Are there new data that could inform the key questions that might not be addressed in the conclusions? An analysis of US nationally representative prescription database found adherence was better with the once daily bupropion XL than with the twice-daily bupropion SR formulation (Stang, 2007).
Key Question 5: How do the efficacy, effectiveness, or harms of treatment with antidepressants for a depressive syndrome differ for the following subpopulations: * Elderly or very elderly patients; *Other demographic groups (defined by age, ethnic or racial groups, and sex); * Patients with medical comorbidities (e.g., ischemic heart disease, cancer)?
No major differences in efficacy and effectiveness exist among second-generation antidepressants in elderly or very elderly populations. Indirect evidence suggests that efficacy among second-generation antidepressants does not differ between men and women. | An analysis of 10 double blind head-to-head trials of patients with major depressive disorder found no age-related difference in efficacy between bupropion and the SSRIs. There is greater improvement in efficacy in anxious/somatic symptoms of depression among women during SSRIs treatment than men (Papakostas, 2007). Analyses of RCTs, comparing escitalopram with placebo or other antidepressants (citalopram, fluoxetine, paroxetine, sertraline, venlafaxine), found the risk of AEs due to escitalopram was no higher in special patient populations, such as the elderly or those with hepatic dysfunction (Baldwin, 2007). An open-label study of 62 patients aged 60+ with major depressive disorder, treated with venlafaxine XR for 12 weeks, found 24% (95% CI 7.3% to 40.7%) of initially normotensive participants and 54% (95% CI 34.3% to 74%) of those with preexisting hypertension experienced an increase in blood pressure. 29% (95% CI 14.6% to 43.4%) developed orthostatic hypotension. 2 experienced a clinically significant increase in QTc interval. 1 participant reported new- onset mild dizziness, 4 reported new-onset tachycardia or palpitation. Overall, 17 unique participants (28.8%, 95% CI 17.3% to 40.4%) experienced a new-onset cardiovascular problem. Systematic monitoring of cardiovascular parameters during treatment with venlafaxine-XR should be strongly recommended, especially in the elderly (Johnson, 2006). An analysis of the Medical Expenditure Panel Survey for 1996–2001 found antidepressant discontinuation during the first 30 days was more common among Hispanics (53.8%) than non-Hispanics (43.7%) (Olfson, 2006). A randomized study of 727 patients with nonpsychotic major depressive disorder and taking any of the following: sustained-release bupropion hydrochloride, sertraline hydrochloride, or extended release venlafaxine hydrochloride, found remission was more likely among whites. Intolerance was less likely for Hispanic participants (Rush, 2008). An analysis of STAR*D patients with nonpsychotic major depressive disorder, treated with citalopram up to 14 weeks, found Black, and to a lesser extent Hispanic patients, had a poorer response to citalopram than white patients. After adjusting for baseline differences, the remission rates seemed to be more similar on the HAM-D, but remained worse for blacks on the Quick Inventory of Depressive Symptomatology-Self Report (QIDS-SR) (Lesser, 2007). A meta-analysis of 7 double-blind placebo controlled trials of patients with MDD who received duloxetine found no significant difference in duloxetine’s treatment effect between African-American and Caucasian patients. Discontinuation rates due to adverse events did not differ significantly between African-Americans and Caucasians. No adverse event led to discontinuation in more than one African-American patient. The rate of occurrence of AEs did not differ significantly between two groups (Bailey, 2006). A clinical trial of 35 adult cancer outpatients with depression, during chemotherapy, found sertraline could significantly decrease mean depression scores, analyzed by Hospital Anxiety and Depression Scale (HADS) and MADRS scales, HADS anxiety scores. No severe adverse effects were observed (Torta, 2008). A meta-analysis of 44 placebo-controlled trials of patients with Parkinson’s disease and depression found SSRIs produced a robust antidepressant effect on moderately depressed Parkinson’s patients (d=0.44, p< 0.05). A modestly positive and significant effect size result was observed with SSRIs on motor function (d=0.34, p<0.05), and there were no significant side effects (d=−0.002, p=0.50). These results show that SSRIs can be used to treat depression without the fear of worsening PD (Frisina, 2005). | 07/2006 SSRIs Active FDA Safety Alert “increased risk for Persistent Pulmonary Hypertension in babies born to mothers who took selective serotonin reuptake inhibitors (SSRIs) and increased risk for Serotonin Syndrome in patients who use SSRIs and triptans together”. | Two experts agreed the conclusion is still valid. One expert responded that s/he does not know. | Conclusion should be updated to include new data on racial/ethnic populations.
Are there new data that could inform the key questions that might not be addressed in the conclusions? Additional comments: A new drug (Desvenlafaxine, Pristiq) has been FDA approved for the treatment of MDD in adults. This drug is not included in the current MMA report. To my knowledge, no head-head trials comparing desvenlafaxine to other second-generation antidepressants exist yet Scope could be broadened to include antipsychotics.

Legend: CI: confidence interval; HADS: Hospital Anxiety and Depression Scale; HAM-A: Hamilton Anxiety Scale; HAM-D: Hamilton Depression Scale; HRQOL: health-related quality of life; ITT: intention to treat; MADRS: Montgomery-Åsberg Depression Rating Scale; MDD: major depressive disorder; NNT: number needed to treat; QIDS-SR: Quick Inventory of Depressive Symptomatology – Self Report; RCT: randomized controlled trial; RD: rate difference; RR: relative risk; SNRI: serotonin-norepinephrine reuptake inhibitor; SSRI: selective serotonin reuptake inhibitor; STAR*D: Sequenced Treatment Alternatives to Relieve Depression

### References

Acharya N, Rosen AS, et al. Duloxetine: meta-analyses of suicidal behaviors and ideation in clinical trials for major depressive disorder. J Clin Psychopharmacol. 2006;26(6):587-94. [pmid: 17110815].
Bailey RK, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: comparisons of safety and efficacy. J Natl Med Assoc. 2006;98(3):437-47. [pmid: 16573311].
Baldwin DS, Reines EH, et al. Escitalopram therapy for major depression and anxiety disorders. Ann Pharmacother. 2007;41(10):1583-92. [pmid: 17848424].
Cipriani A, Furukawa TA, Salanti G, Geddes JR, Higgins JP, Churchill R, Watanabe N, nakagawa A, Omori IM, McGuire H, Tansella M, Barbui C. Comparative efficacy and acceptability of 12 new-generation antidepressants: a multiple-treatments meta-analysis. Lancet. Feb 28. 2009;373(9665):746-58. [pmid: 19185342].
Dunner DL. Venlafaxine in the Treatment of Unresolved Symptoms of Depression Following Antidepressant Therapy. Primary Psychiatry. 2007;14(3):39-49.
Eckert L, Falissard B. Using meta-regression in performing indirect-comparisons: comparing escitalopram with venlafaxine XR. Curr Med Res Opin. 2006;22(11):2313-21. [pmid: 17076991].
Fava M, Rush AJ, et al. Difference in treatment outcome in outpatients with anxious versus nonanxious depression: a STAR*D report. Am J Psychiatry. 2008;165(3):342-51. [pmid: 18172020].
Frisina P. 2005. The effects of antidepressants on the health outcomes of Parkinson’s disease patients: A meta-analysis. New York. City University of New York. PHD: 138.
Hansen R, Gaynes B, et al. Meta-analysis of major depressive disorder relapse and recurrence with second-generation antidepressants. Psychiatr Serv. 2008;59(10):1121-30. [pmid: 18832497].
Himei A, Okamura T. Discontinuation syndrome associated with paroxetine in depressed patients: a retrospective analysis of factors involved in the occurrence of the syndrome. CNS Drugs. 2006;20(8):665-72. [pmid: 16863271].
Johnson EM, Whyte E, et al. Cardiovascular changes associated with venlafaxine in the treatment of late-life depression. Am J Geriatr Psychiatry. 2006;14(9):796-802. [pmid: 16943176].
Katzman MA, Tricco AC, et al. Paroxetine versus placebo and other agents for depressive disorders: a systematic review and meta-analysis. J Clin Psychiatry. 2007;68(12):1845-59. [pmid: 18162015].
Lancon C, Verpillat P, et al. Escitalopram in major depressive disorder: clinical benefits and cost effectiveness versus citalopram. International Journal of Psychiatry in Clinical Practice. 2007;11(1):44-52.
Lesser IM, Castro DB, et al. Ethnicity/race and outcome in the treatment of depression: results from STAR*D. Med Care. 2007;45(11):1043-51. [pmid: 18049344].
Lin CH, Lin KS, et al. Time to rehospitalization in patients with major depressive disorder taking venlafaxine or fluoxetine. J Clin Psychiatry. 2008;69(1):54-9. [pmid: 18312038].
Nemeroff CB, Entsuah R, et al. Comprehensive analysis of remission (COMPARE) with venlafaxine versus SSRIs. Biol Psychiatry. 2008;63(4):424-34. [pmid: 17888885].
Olfson M, Marcus SC, et al. Antidepressant drug therapy and suicide in severely depressed children and adults: A case-control study. Arch Gen Psychiatry. 2006;63(8):865-72. [pmid: 16894062].
Olfson M, Marcus SC, et al. Continuity of antidepressant treatment for adults with depression in the United States. Am J Psychiatry. 2006;163(1):101-8. [pmid: 16390896].
Papakostas GI, Kornstein SG, et al. Relative antidepressant efficacy of bupropion and the selective serotonin reuptake inhibitors in major depressive disorder: gender-age interactions. Int Clin Psychopharmacol. 2007;22(4):226-9. [pmid: 17519646].
Rahme E, Dasgupta K, et al. Risks of suicide and poisoning among elderly patients prescribed selective serotonin reuptake inhibitors: a retrospective cohort study. J Clin Psychiatry. 2008;69(3):349-57. [pmid: 18278986].
Raskin J, Wiltse CG, et al. Efficacy of duloxetine on cognition, depression, and pain in elderly patients with major depressive disorder: an 8-week, double-blind, placebo-controlled trial. Am J Psychiatry. 2007;164(6):900-9. [pmid: 17541049].
Roca Benassar M, Baldomero E Baca. Response and remission in depressive patients with anxiety symptoms treated with venlafaxine extended release in primary care. Actas Esp Psiquiatr. 2006;34(3):162-8. [pmid: 16736389].
Rubino A, Roskell N, et al. Risk of suicide during treatment with venlafaxine, citalopram, fluoxetine, and dothiepin: retrospective cohort study. BMJ. 2007;334(7587):242. [pmid: 17164297].
Rush AJ, Wisniewski SR, et al. Selecting among second-step antidepressant medication monotherapies: predictive value of clinical, demographic, or first-step treatment features. Arch Gen Psychiatry. 2008;65(8):870-80. [pmid: 18678792].
Shelton RC, Andorn AC, et al. Evidence for the efficacy of duloxetine in treating mild, moderate, and severe depression. Int Clin Psychopharmacol. 2007;22(6):348-55. [pmid: 17917553].
Sondergard L, Lopez AG, et al. Continued antidepressant treatment and suicide in patients with depressive disorder. Arch Suicide Res. 2007;11(2):163-75. [pmid: 17453694].
Stang P, Young S, et al. Better patient persistence with once-daily bupropion compared with twice-daily bupropion. Am J Ther. 2007;14(1):20-4. [pmid: 17303971].
Szanto K, Mulsant BH, et al. Emergence, persistence, and resolution of suicidal ideation during treatment of depression in old age. J Affect Disord. 2007;98(1–2):153-61. [pmid: 16934334].
Thase ME, Pritchett YL, et al. Efficacy of duloxetine and selective serotonin reuptake inhibitors: comparisons as assessed by remission rates in patients with major depressive disorder. J Clin Psychopharmacol. 2007;27(6):672-6. [pmid: 18004135].
Torta R, Siri I, et al. Sertraline effectiveness and safety in depressed oncological patients. Support Care Cancer. 2008;16(1):83-91. [pmid: 17874143].
Wu YS, Chen YC, et al. Venlafaxine vs. paroxetine in the acute phase of treatment for major depressive disorder among Han Chinese population in Taiwan. J Clin Pharm Ther. 2007;32(4):353-63. [pmid: 17635337].
Zimmerman M, Thongy T. How often do SSRIs and other new-generation antidepressants lose their effect during continuation treatment? Evidence suggesting the rate of true tachyphylaxis during continuation treatment is low. J Clin Psychiatry. 2007;68(8):1271-6. [pmid: 17854252].

## CER 9. Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease

For this assessment, a limited literature search was conducted for the years 2006–2008. This search included the five generalist journals listed in the Methods and four specialty journals (as recommended by the subject matter experts): Circulation; Journal of the American College of Cardiology; Heart; American Journal of Cardiology. The search identified 252 titles, of which 42 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of the 42 selected for further review, all were abstracted into an evidence table (Attachment II). An additional 7 articles were included at the suggestion of the experts.

We consulted the project leader and 4 additional subject matter experts for their assessments. Of these 5 individuals, four responded. Importanlty, the project leader indicated that AHRQ was already supporting an individual patient-level data meta-analysis to better refine estimates of comparative effectiveness for subgroups of patients. This meta-analysis was recently published and, in the view of the project leader, constitutes the update (Hlatky et al, 2009).

Table 2.7 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.7 CER 9. Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SC EPC
Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | EPC Investigator, 3 Other Experts | Conclusion from SC EPC
Key Question 1 1a: In patients with ischemic heart disease and angiographically proven single or multi-vessel disease, what is the effectiveness of PCI compared with CABG in reducing the occurrence of adverse objective outcomes and improving subjective outcomes?
There were no significant differences in procedural survival when trials were subdivided into balloon-era and stent-era studies or into single vessel-disease and multi-vessel-disease patient populations. Procedural survival for both percutaneous coronary interventions (PCI) and coronary artery bypass graft (CABG) was high for both procedures and did not differ significantly. In large registries, procedural survival has increased significantly over time. Short- term procedural survival after PCI generally exceeded that of CABG in both earlier and more recent time intervals. | Hannan, 2008 found, based on the NY State Registry, no difference in procedural mortality. (Data from this registry were already included in the evidence report and the new report was not significantly different from the prior one.) Takagi, 2008 found no difference in survival between the procedures, based on a meta- analysis of 4 of the included randomized controlled trials (RCT)s of multi-vessel disease. | No new information. | Three experts judge this conclusion as still being valid. One expert is unsure whether the data from the Synergy Between PCI With Taxus and Cardiac Surgery (SYNTAX) or the Stent or Surgery (SoS) Trials are included. These both favor CABG and do not seem to be reflected in this statement. [SoS was included in original CER.] | Conclusion is still valid and this portion of the CER does not need updating.
Freedom from procedural strokes: was significantly higher after PCI than after CABG. | No new evidence. | No new information. | All four experts judge this conclusion to still be valid. | Conclusion is still valid and this portion of the CER does not need updating.
Freedom from procedural myocardial infarctions was not assessed in a consistent fashion across trials RCTs, and there was significant heterogeneity in this outcome. The pooled PCI- CABG difference was small and not statistically significant. | No new evidence. | No new information. | Three experts judge this conclusion as still being valid. One expert believes the key challenge is the definition across the modalities. Current approaches, as used in the Clinical Outcomes Utilizing Revascularization and Aggressive Drug Evaluation (COURAGE) seem reasonable. This is, however, probably not a clearly important outcome in the era of very sensitive biomarkers. NOTE: COURAGE compared PCI + optimal medical therapy with optimal medical therapy. No CABG was conducted in the study. | Conclusion is still valid and this portion of the CER does not need updating.
1b: Over what period of time are the comparative benefits of PCI and CABG sustained?
Long-term survival across all RCTs between 1 and 5 years of followup was similar in CABG-assigned and PCI- assigned patients, with less than 1-percent absolute PCI- CABG survival difference at each time point. The long-term survival difference between PCI and CABG was significantly different in the older RCTs that relied on balloon angioplasty, but not in the more recent RCTs that employed coronary stents. Stent-era trials included more patients with single-vessel disease, however, and had shorter followup than balloon- era trials. | A 6-year follow up study of the SoS) Trial and 5 year data from other RCTs show no difference in survival (Booth, 2008; Hlatky, 2008). The SoS Trial of patients with multivessel disease, comparing PCI with CABG, found a continuing survival advantage for patients managed with CABG at a median follow-up of 6 years (Booth, 2008). When the SoS data were added to the 5 year outcome data from the other PCI vs. surgery trials the overall pooled result was not significantly changed, which did not show a survival differences between CABG and PCI (Hlatky, 2008). A new report from the NY State Registry confirmed slightly improved survival with CABG at 18 months compared with PCI. (Data from this registry were already included in the evidence report and the new report was not significantly different from the prior one) (Hannan, 2008). Takagi, 2008 found no difference in survival between the procedures, based on a meta- analysis of 4 of the included RCTs of multi-vessel disease (Takagi, 2008). | No new information. | Three experts judged this conclusion as still being valid. One expert cited SoS trial was added to CER meta-analysis results (Booth, 2008). One expert cited additional support (Bravata, 2007). (This article was derived from the CER) One expert believes the conclusion is no longer valid based on SoS favoring CABG, and SYNTAX does so for the combined endpoint. Drug-eluting stents (DES) were not used in SoS, only bare metal stents (BMS). | Conclusion is possibly out of date and this portion of the CER may need updating, due to differing expert opinion.
Freedom from angina was significantly greater after CABG than after PCI in randomized trials between 1 and 5 years post-procedure. Freedom from repeat revascularization was significantly greater after CABG than after PCI at 1 and 5 years. The gap between PCI and CABG in repeat revascularization procedures narrowed in more recent trials that used coronary stents. Freedom from myocardial infarction was small, 1 percent between 1 and 5 years after the procedure and did not achieve statistical significance. | No new evidence found for freedom from angina. A new report from the NY State Registry also confirmed a higher revascularization rate among stent recipients than CABG patients (Hannan, 2008). (Data from this registry were already included in the evidence report.) A meta-analysis of four of the included RCTs of multi-vessel disease found increased repeat revascularization after CABG than after PCI (Takagi, 2008). No new evidence found for freedom from myocardial infraction Initial analysis of the SYNTAX trial found, at 12 months, repeat revascularization was more frequent with PCI than CABG, while the increase in repeat revascularization for PCI compared to CABG was lower than in any prior trials. Stroke was more frequent in the CABG group. Combined safety in terms of death, MI and stroke remained the same for PCI and CABG. Sub-analysis of patients with triple-vessel disease, overall 12- month Major Adverse Cardiovascular and Cerebrovascular Events (composite of death, stroke, MI, and repeat revascularization) rates were significantly higher in those who received PCI compared with CABG. The rates of MI and repeat revascularization were also higher in the PCI arm. (Walle, 2008; Feldman, 2008; Kahn, 2009) | No new information. | One expert judged the conclusion is still valid One expert cited additional support (Bravata, 2007). (This article was derived from the CER) One expert believes this conclusion is the key. One expert judged the conclusion to be no longer valid. This expert cited the SYNTAX trial comparing multivessel stenting (including left main descending artery (LM)) vs. CABG. The trial found statistically greater MI rate vs. CABG in the subgroup of patients undergoing multivessel stenting. | Conclusion is possibly out of date and this portion of the CER may need updating, due to differing expert opinion.
In general, quality-of-life scores improved to a significantly greater extent after CABG than after PCI between 6 months and 3 years of followup but equalized thereafter. The degree of improvement in quality of life was correlated with relief of angina. | Favarato, 2007 found the CABG group had greater improvements in Short Form (SF)36- measured quality of life (QOL) than the PCI group (Favarato, 2007). | No new information. | Three experts judged this conclusion to still be valid. One expert believes the conclusion is no longer valid. Registries support a slower rate of improvement in QoL in CABG than PCI, but the overall benefits favor CABG. Almost all of the differences in QoL at one year are attributable to restenosis – which is minimized in DES. Haven’t seen recent registries with QoL outcomes comparing CABG and PCI in the DES era (Borkon, 2002). | Conclusion is possibly out of date and this portion of the CER may need updating, due to differing expert opinion.
Key Question 2: Is there evidence that the comparative effectiveness of PCI and CABG varies based on: 2a. Age, sex, race, or other demographic risk factors?
There was little evidence from RCTs to gauge whether the comparative effectiveness of CABG and PCI varies according to patient or provider characteristics. Older patients had more procedural complications from both PCI and CABG, especially stroke. Patients aged 65 years and older had lower long-term survival compared with younger patients. Roughly 27 percent of the patients in randomized trials were women, and their outcomes were similar to those among men in the trials that examined outcomes by gender. Outcomes after PCI and CABG according to race were analyzed only by the BARI (Bypass Angioplasty Revascularization Investigation) trial and registry, which found African-American patients had significantly lower overall survival, irrespective of treatment with PCI or CABG. | No new evidence found for age, gender, race. | No new information. | Four experts judged this conclusion to still be valid. One expert cited additional support (Lawrence, 2007). | Conclusion is still valid and this portion of the CER does not need updating.
2b. Coronary disease risk factors, diabetes, or other comorbid disease?
In large clinical registries, comparative survival after PCI or CABG varied significantly according to the extent of coronary disease. Survival was significantly better after PCI in patients with single-vessel disease that did not involve the proximal left anterior descending artery (LAD), and survival was significantly better after CABG in patients with extensive triple-vessel or left main disease. In analyses from large clinical registries of patients with middle spectrum CAD severity, there was no difference in survival after PCI or CABG. | A new report from the NY State Registry (Hannan, 2008) was similar to what was seen in other prior registries—namely that patients with more extensive disease had improved survival with CABG. included in the evidence report.) | No new information. | Three experts judge the conclusion as not being valid anymore. One expert is working on a Technical Addendum to the original Evidence Report that is really a piece of original research – namely a collaboration among all the large clinical trials to pool individual patient data and look very carefully at all the patient subgroup outcomes. One expert cited SYNTAX trial comparing evaluated multivessel stenting (including LM) vs. CABG. The trial didn’t find statistically difference in survival in LM stenting vs. CABG and in multivessel stenting vs. CABG. One expert judges the conclusion as still being valid. | Conclusion is probably out of date and this portion of the CER needs updating based on the majority of expert opinion.
Survival at 1 and 5 years in patients with diabetes was reported by six trials. The BARI trial reported a significant survival advantage for patients with diabetes assigned to CABG: 5-year survival of 80 percent with CABG vs. 65 percent with PCI. None of the other trials found as dramatic a difference in survival between patients with and without diabetes. | No new evidence other than possible new data from Stanford-UCSF EPC (Hlatky, 2008). | No new information. | All four experts judge this conclusion to still be valid. In July 2008, CER authors added SoS and Arterial Therapy Revascularization Study (ARTS) trials to their meta-analyses on diabetes patients. There was no difference in conclusions. (Hlatky, 2008) One expert reveals that Bypass Angioplasty Revascularization Investigation Type 2 Diabetes (BARI-2D- is a In July 2008, CER authors added SoS and Arterial Therapy Revascularization Study (ARTS) trials to their meta-analyses on diabetes patients. There was no difference in conclusions. (Hlatky, 2008) One expert reveals that Bypass Angioplasty Revascularization Investigation Type 2 Diabetes (BARI-2D- is a program to study whether, in patients with Type 2 Diabetes, initial treatment with angioplasty or bypass surgery is better than initial treatment with a medical program) is to be released this year. | Conclusion is still valid and this portion of the CER does not need updating.
In general, obesity was not consistently associated with significant differences in comparative effectiveness of PCI and CABG in the two trials that reported outcomes by body mass index. | No new evidence. | No new information. | Two experts agreed that the conclusion is no longer valid. One expert is working on a Technical Addendum to the original Evidence Report that is really a piece of original research – namely a collaboration among all the large clinical trials to pool individual patient data and look very carefully at all the patient subgroup outcomes. Two experts agreed that the conclusion is still valid. | Conclusion is possibly out of date and this portion of the CER may need updating, based on the expected availability of the individual patient level meta analysis that will have greater power to assess comparative effectiveness in subgroups.
2c. Angiographic-specific factors including, but not limited to, the number of diseased vessels amenable to bypass or stenting, vessel territory of stenoses (e.g., left main or anterior descending coronary arteries, right coronary artery, circumflex coronary artery), diffuse vs. focal stenoses, left ventricular function, or prior revascularization procedures?
There was no significant difference in the comparative survival benefit when RCTs were subdivided into those enrolling patients with single-vessel proximal LAD disease and those enrolling patients with multi-vessel disease. | A new study based on the NY State Registry (Hannan, 2008) found no difference in procedural mortality. (Data from this registry were already included in the evidence report and the new report was not significantly different from the prior one.) Takagi, 2008 found no difference in survival between the procedures, based on a meta-analysis of 4 of the included RCTs of multi-vessel disease (Takagi, 2008). | No new information. | All four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
In large clinical registries, comparative survival after PCI or CABG varied significantly with the extent of coronary disease, with better survival after PCI in patients with the least extensive coronary disease and better survival after CABG in patients with the most extensive disease. | No new evidence. | No new information. | Two experts agreed this conclusion is still valid. One expert cited additional support. (Lawrence, 2007) One expert suggested that the conclusions are no longer very relevant, given that PCI is almost universally done, when possible, among those with single vessel disease. One expert believes the conclusion is no longer valid and cites the SYNTAX trial comparing multivessel stenting (including LM) to CABG. The trial didn’t find statistical difference in survival in LM stenting vs. CABG and in multivessel stenting vs. CABG | Conclusion is possibly out of date and this portion of the CER may need updating, due to differing expert opinion.
Most trials comparing PCI and CABG randomized patients with relatively preserved left ventricular function and a low prevalence of heart failure. The limited range of ejection fractions within the trials precludes a stringent test of whether the comparative effectiveness of PCI and CABG varies according to left ventricular function. | No new evidence for left ventricular function. | No new information. | All four experts agreed this conclusion as still valid. One expert mentioned that while not directly comparing PCI and CABG, the results of the Surgical Treatment for IschemiC Heart failure (STICH) trial might be released this year (2009). | Conclusion is still valid and this portion of the CER does not need updating.
2d. CABG-specific factors including, but not limited to, cardiopulmonary bypass mode (normothermic vs. hypothermic), type of cardioplegia used (blood vs. crystalloid), or use of saphenous vein grafts, single or bilateral internal mammary artery grafts, or other types of bypass grafts?
Use of minimally invasive techniques: “Minimally invasive” surgery, which is performed through a small thoracotomy incision on a beating heart, was compared with PCI in eight small RCTs. These trials enrolled patients with single-vessel proximal LAD disease (predominantly or exclusively) and generally used PCI with stents as the comparator. These trials showed no significant differences in survival between PCI and CABG over a relatively short followup period. | No new evidence. | No new information. | All four experts agreed this conclusion is still valid. One expert noted that there are some new data favoring open procedures, not positive. | Conclusion is still valid and this portion of the CER does not need updating.
Standard CABG was used in all trials that enrolled patients with multi-vessel disease, with variable use of left internal mammary grafting, ranging from a low of 37 percent in the early GABI study to over 90 percent. The 1-year survival advantage for CABG vs. PCI increased along with the proportion of internal mammary artery grafts used, but this trend was not statistically significant and not evident at 5 years. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. One expert concludes the use of left internal mammary arteries (LIMAs) is now a quality indicator for the Society of Thoracic Surgeons (STS) and this does not seem as relevant an issue any more. | Conclusion is still valid and this portion of the CER does not need updating.
2e. Clinical presentation (e.g., stable angina or unstable angina based on New York Heart Association functional class I–IV, acute coronary syndrome, cardiogenic shock, acute myocardial infarction with or without ST elevation, or silent ischemia)?
Comparative survival after PCI and CABG was not consistently different between patients with stable or unstable angina. | No new evidence. | No new information. | All four experts agreed this conclusion is still valid. One expert cited (Hochholzer, 2008). | Conclusion is still valid and this portion of the CER does not need updating.
2f. Adjunctive medical therapies, such as short-term intravenous or oral antiplatelet drugs, or long-term use of oral antiplatelet drugs?
The RCTs did not report comparative effectiveness data based on the use of adjunctive medical therapy for PCI or CABG. It is uncertain whether patients who have undergone CABG are as likely as patients who have undergone PCI to comply with recommendations for long-term use of aspirin, beta-blockers, angiotensin-converting enzyme inhibitors, and statins. There is relatively little evidence on this question from randomized trials; however, the Duke Database, a large observational registry of patients receiving both procedures, reports relatively similar use of evidence-based therapies after PCI and CABG. | No new evidence. | No new information. | All four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
2g. Process characteristics such as provider volume, hospital volume, and setting (e.g., academic vs. community)?
There was considerable evidence that procedural outcomes of both CABG and PCI were significantly worse in low-volume hospitals and with low-volume operators. This relationship remained significant for PCI, even as procedural risk has been reduced by the availability of coronary stents and adjunctive therapy. The magnitude of association of procedural outcomes with volume of PCI and CABG may be only modest, however, at least among sufficiently experienced centers and operators. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. One expert believes the conclusion does not seem to be as important in the current era. Also of note, substantially more data have emerged supporting the use of PCI without onsite CABG. Not sure if that is relevant to this work. | Conclusion is still valid and this portion of the CER does not need updating.
2h. Prior PCI or CABG revascularization procedures?
Most randomized trials excluded patients with prior CABG, but one randomized trial and several clinical registries have compared PCI with re-do CABG in patients with a prior CABG. In the AWESOME (Angina With Extremely Serious Operative Mortality Evaluation) trial, patients with prior CABG were randomized to either re-do CABG or PCI. While procedural survival was significantly lower in the patients assigned to CABG 3-year survival did not differ significantly. A similar pattern has been reported by 3 large clinical registry studies. Procedural mortality was higher for re-do CABG than for PCI, but survival at 5 to 6 years of followup did not differ significantly. | No new evidence. | No new information. | All four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? Additional comments: 1) Meta-analysis of PCI (mostly BMS) vs. CABG RCTs demonstrated lower revascularization rates and improved angina relief but increased stroke rate in CABG; no survival difference @ 10 yrs (including in diabetics). Ann Intern Med. 2007 Nov 20;147(10):703–16. (This article was derived from the CER) 2) Small cohort studies & meta-analyses demonstrate no early or midterm difference in the treatment of unprotected LM stenosis between PCI and CABG. Am J Cardiol. 2008 Jan 15;101(2):169–72., Am Heart J. 2008 Feb;155(2):274–83., J Am Coll Cardiol. 2008 Feb 5;51(5):538–45 *The remainder of new studies comparing PCI & CABG were case series or retrospective (generally single-center) cohort studies.

Legend: ARTS: Arterial Revascularization Therapy Study; AWESOME: Angina With Extremely Serious Operative Mortality Evaluation; BARI: Bypass Angioplasty Revascularization Investigation ; BARI-2D: Bypass Angioplasty Revascularization Investigation 2 Diabetes trial; BMS: bare metal stent; CABG: coronary artery bypass graft; COURAGE: Clinical Outcomes Utilizing Revascularization and Aggressive Drug Evaluation; DES: drug-eluting stent; LAD: left anterior descending artery; LIMA: left internal mammary artery; LM: left main descending artery; PCI: percutaneous coronary intervention; QoL: quality of life; RCT: randomized controlled trial; SF: Short Form; SoS: Stent or Surgery; STICH: Surgical Treatment for IschemiC Heart failure; STS: Society of Thoracic Surgeons; SYNTAX: Synergy Between PCI With Taxus and Cardiac Surgery

### References

The final 10-year follow-up results from the BARI randomized trial. J Am Coll Cardiol. Apr. 17. 2007;49(15):1600-1606. [pmid: 17433949].
Abbate A, Lipinski MJ. Drug-eluting stents vs. coronary-artery bypass grafting. N Engl J Med. Jun. 12. 2008;358(24):2642. author reply 2643–2644.
Aziz O, Rao C, Panesar SS, et al. Meta-analysis of minimally invasive internal thoracic artery bypass versus percutaneous revascularisation for isolated lesions of the left anterior descending artery. BMJ. Mar 24. 2007;334(7594):617. [pmid: 17337458].
Booth J, Clayton T, Pepper J, et al. Randomized, controlled trial of coronary artery bypass surgery versus percutaneous coronary intervention in patients with multivessel coronary artery disease: six-year follow-up from the Stent or Surgery Trial (SoS). Circulation. Jul 22. 2008;118(4):381-388. [pmid: 18606919].
Borkon AM, Muehlebach GF, House J, Marso SP, Spertus JA. A comparison of the recovery of health status after percutaneous coronary intervention and coronary artery bypass. Ann Thorac Surg. Nov. 2002. 74(5):1526-1530. discussion 1530. [pmid: 12440603].
Burack JH. Drug-eluting stents vs. coronary-artery bypass grafting. N Engl J Med. Jun. 12. 2008;358(24):2643. author reply 2643–2644.
Dacey LJ, Likosky DS, Ryan TJ Jr, et al. Long-term survival after surgery versus percutaneous intervention in octogenarians with multivessel coronary disease. Ann Thorac Surg. Dec. 2007;84(6):1904-1911. discussion 1904–1911. [pmid: 18036905].
Daemen J, Kukreja N, Serruys PW. Drug-eluting stents vs. coronary-artery bypass grafting. N Engl J Med. Jun. 12. 2008;358(24):2641-2642. author reply 2643–2644. [pmid: 18550881].
Farkouh ME DG, Leon MB, Smith C, Nesto R, Buse JB, Cohen DJ, Mahoney E, Sleeper L, King S, Domanski M, McKinlay S, Fuster V. Design of the Future REvascularization Evaluation in patients with Diabetes mellitus: Optimal management of Multivessel disease (FREEDOM) Trial. American heart journal. 2008;155(2):215-223. [pmid: 18215589].
Favarato ME HW, Boden WE, Lopes N, Nogueira CR, Takiuti M, Gois AF, Borges JC, Favarato D, Aldrighi JM, Oliveira SA, Ramires JA. Quality of life in patients with symptomatic multivessel coronary artery disease: a comparative post hoc analyses of medical, angioplasty or surgical strategies-MASS II trial. International journal of cardiology. 2007;116(3):364-370. [pmid: 16876891].
Feldman T. The Syntax Trial. CathLab Digest. Oct. 06. 2008.
Harjai KJ. Drug-eluting stents vs. coronary-artery bypass grafting. N Engl J Med. Jun. 12. 2008;358(24):2642-2643. author reply 2643–2644.
Hlatky MA, Boothroyd DB, Bravata DM, Boersma E, Booth J, Brooks MM, Carrié D, Clayton TC, Danchin N, Flather M, Hamm CW, Hueb WA, Kähler J, Kelsey SF, King SB, Kosinski AS, Lopes N, McDonald KM, Rodriguez A, Serruys P, Sigwart U, Stables RH, Owens DK, Pocock SJ. Coronary artery bypass surgery compared with percutaneous coronary interventions for multivessel disease: a collaborative analysis of individual patient data from ten randomised trials. Lancet. Apr 4. 2009;373(9670):1190-7. [pmid: 19303634].
Hlatky MA, Bravata DM. Stents or surgery? New data on the comparative outcomes of percutaneous coronary intervention and coronary artery bypass graft surgery. Circulation. Jul 22. 2008;118(4):325-327. [pmid: 18645064].
Hochholzer W, Buettner HJ, Trenk D, et al. Percutaneous coronary intervention versus coronary artery bypass grafting as primary revascularization in patients with acute coronary syndrome. Am J Cardiol. Jul 15. 2008;102(2):173-179. [pmid: 18602516].
Holmes DR KL, Brooks MM, Kip KE, Schaff HV, Detre KM, Frye RL. Bypass Angioplasty Revascularization Investigation (BARI) Investigators. The effect of coronary artery bypass grafting on specific causes of long-term mortality in the Bypass Angioplasty Revascularization Investigation. The Journal of thoracic and cardiovascular surgery. 2007;134(1):38-46. [pmid: 17599484].
Hueb W, Lopes NH, Gersh BJ, et al. Five-year follow-up of the Medicine, Angioplasty, or Surgery Study (MASS II): a randomized controlled clinical trial of 3 therapeutic strategies for multivessel coronary artery disease. Circulation. Mar 6. 2007;115(9):1082-1089. [pmid: 17339566].
Javaid A, Steinberg DH, Buch AN, et al. Outcomes of coronary artery bypass grafting versus percutaneous coronary intervention with drug-eluting stents for patients with multivessel coronary artery disease. Circulation. Sep 11. 2007;116(11 Suppl):I200-206. [pmid: 17846304].
Jones RH. Percutaneous intervention vs. coronary-artery bypass grafting in left main coronary disease. N Engl J Med. Apr 24. 2008;358(17):1851-1853. [pmid: 18378518].
Kahn J. Year in review: key trials highlight role of PCI, DES in 2008. Tctmd-The Source for International Cardiovascular News and Education. Jan. 05. 2009.
King SB 3rd. Five-year follow-up of the Medicine, Angioplasty, or Surgery Study (MASS-II): prologue to COURAGE. Circulation. Mar 6. 2007;115(9):1064-1066. [pmid: 17339563].
Lee MS, Kapoor N, Jamal F, et al. Comparison of coronary artery bypass surgery with percutaneous coronary intervention with drug-eluting stents for unprotected left main coronary artery disease. J Am Coll Cardiol. Feb 21. 2006;47(4):864-870. [pmid: 16487857].
Meliga E, Valgimigli M, Buszman P, Serruys PW. Percutaneous coronary intervention or coronary artery bypass graft for unprotected left main coronary artery disease: the endless debate. J Am Coll Cardiol. Aug. 12. 2008;52(7):582-584. author reply 584–586. [pmid: 18687257].
Ng AC, Kritharides L. Drug-eluting stents vs. coronary-artery bypass grafting. N Engl J Med. Jun. 12. 2008;358(24):2643. author reply 2643–2644.
Nicolau JC, M-NJ, Giraldez RR, Golin V, Rabelo A, Ramires JA. InTIME-2 investigators. A comparison of percutaneous coronary intervention and surgical revascularization after fibrinolysis for acute myocardial infarction. Insights from the InTIME-2 trial. International journal of cardiology. 2007;116(3):383-388. [pmid: 17049642].
Pocar M, Donatelli F, Moneta A. Stents versus bypass grafting for left main coronary artery disease. N Engl J Med. Jul. 24. 2008;359(4):423. author reply 425.
Pocar M, Quaini E, Donatelli F. Letter by Pocar et al regarding article, “Percutaneous treatment with drug-eluting stent implantation versus bypass surgery for unprotected left main stenosis: a single-center experience”. Circulation. Nov. 7. 2006;114(19):e574. author reply e575. [pmid: 17088470].
Radford MJ. Percutaneous coronary intervention “dominates” coronary artery bypass graft surgery for high-risk patients: good news for patients, a challenge for healthcare planners. Circulation. Sep 19. 2006;114(12):1229-1231. [pmid: 16982950].
Rao C, Aziz O, Panesar SS, et al. Cost effectiveness analysis of minimally invasive internal thoracic artery bypass versus percutaneous revascularisation for isolated lesions of the left anterior descending artery. BMJ. Mar 24. 2007;334(7594):621. [pmid: 17337457].
Scott N, Wolfenden H, Knight J, Linacre R, Bidstrup B, Maddern G. Systematic review of off-pump coronary artery bypass surgery with the aid of the Octopus Tissue Stabilizer. Eur J Cardiothorac Surg. 2002;21:804-817. [pmid: 12062268].
Soares PR, Hueb WA, Lemos PA, et al. Coronary revascularization (surgical or percutaneous) decreases mortality after the first year in diabetic subjects but not in nondiabetic subjects with multivessel disease: an analysis from the Medicine, Angioplasty, or Surgery Study (MASS II). Circulation. Jul 4. 2006;114(1 Suppl):I420-424. [pmid: 16820611].
Stroupe KT, Morrison DA, Hlatky MA, et al. Cost-effectiveness of coronary artery bypass grafts versus percutaneous coronary intervention for revascularization of high-risk patients. Circulation. Sep 19. 2006;114(12):1251-1257. [pmid: 16966588].
Taggart DP, Kaul S, Boden WE, et al. Revascularization for unprotected left main stem coronary artery stenosis stenting or surgery. J Am Coll Cardiol. Mar 4. 2008;51(9):885-892. [pmid: 18308155].
Takagi H, Kawai N, Umemoto T. Meta-analysis of four randomized controlled trials on long-term outcomes of coronary artery bypass grafting versus percutaneous coronary intervention with stenting for multivessel coronary artery disease. Am J Cardiol. May 1. 2008;101(9):1259-1262. [pmid: 18435954].
Tayek JA. Stents versus bypass grafting for left main coronary artery disease. N Engl J Med. Jul. 24. 2008;359(4):424. author reply 425.
Tomoda H. Stents versus bypass grafting for left main coronary artery disease. N Engl J Med. Jul. 24. 2008;359(4):423-424. author reply 425.
Van de Walle S, Kabir T, Zuffi A, Roguelov C, Eeckhout E. Interventional cardiology highlights of the european Society of Cardiology congress, 2008. EuroIntervention. Nov. 2008;4(3):309-310. [pmid: 19110802].
Ward HB KR, Thottapurathu L, Moritz TE, Larsen GC, Pierpont G, Santilli S, Goldman S, Krupski WC, Littooy F, Reda DJ, McFalls EO. Coronary artery bypass grafting is superior to percutaneous coronary intervention in prevention of perioperative myocardial infarctions during subsequent vascular surgery. The Annals of thoracic surgery. 2006;82(3):795-800. [pmid: 16928485].
Weintraub WS. Evaluating the risk of coronary surgery and percutaneous coronary intervention. J Am Coll Cardiol. Feb 7. 2006;47(3):669-671. [pmid: 16458153].

## CER 10. Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension

For this assessment, a limited literature search was conducted for the years 2006–2008. This search included the five generalist journals listed in the Methods and five specialty journals (as recommended by the subject matter experts): Stroke; Hypertension; Circulation; Journal of the American College of Cardiology; Heart; American Journal of Cardiology. The search identified 285 titles, of which 49 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of those selected for further review, 48 were abstracted. The remaining article was rejected because it had already been included in the earlier report or did not include a comparison of interest. Three additional articles were also included at the suggestion of the experts, for a total of 51.

We consulted the project lead and 4 additional subject matter experts (the report does not list the TEP composition) for their assessments. Of these 5 individuals, three responded.

Table 2.8 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.8 CER 10. Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SC EPC
Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | 3 Experts | Conclusion from SC EPC
Key Question 1. For adult patients with essential hypertension, how do ACEIs and ARBs differ in blood pressure control, cardiovascular risk reduction, cardiovascular events, quality of life, and other outcomes?
ACEIs and ARBs appear to have similar long-term effects on blood pressure among individuals with essential hypertension. | A large randomized controlled trial (RCT), ONTARGET, comparing telmisartan (an ARB) with ramipril (an ACEI), found slightly lower BP attained with telmisartan 80 than ramipril 10 over 4+ yrs of follow up. The ONTARGET study also showed noninferiority in BP-independent CV protection. The TRANSCEND Study showed no significant effect of ARB for primary or secondary prevention (ONTARGET Investigators, 2008). | No new information. | One expert cited 2 large randomized controlled trials (RCT) comparing telmisartan (an ARB) with ramipril (an ACEI), the ONTARGET and TRANSCEND trials. This study concludes slightly lower BP attained with Telmisartan 80 than Ramipril 10 over 4+ yrs of follow up ON TARGET study showed noninferiority in BP independent CV protection, TRANSCEND study showed no significant impact of ARB for primary or secondary prevention (ONTARGET Investigators, 2008). Two experts judged the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Due to insufficient numbers of deaths or major cardiovascular events in the included studies, it was not possible to discern any differential effect of ACEIs vs. ARBs for these critical outcomes. | A case-control study of the association of ACEIs and aortic rupture in patients with AAA found that patients on ACEIs had lower risk of rupture than patients on ARBs, but this was not a statistically significant finding (OR 1.24; 0.71–2.18) (Hackam, 2006). Two reviews evaluated the association of ARBs and myocardial infarction (MI) (Hall and Strauss, 2007). Only one of these included any direct ACEI vs ARB comparison evidence. The evidence from this would neither change the conclusion or the quality rating for the risk of MI in this report. The ONTARGET trials showed slightly lower BP attained with Telmisartan 80 than Ramipril 10 over 4+ yrs of f/u. ON TARGET study showed noninferiority in BP- independent CV protection, TRANSCEND study showed no significant impact of ARB for primary or secondary prevention (ONTARGET Investigators, 2008). | No new information. | One expert cited the ONTARGET and TRANSCEND trials (ONTARGET Investigators, 2008). Two experts judged the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
No differences were found in measures of general quality of life; this is based on 4 studies, 2 of which did not provide quantitative data. | No new evidence. | No new information. | Three experts judged the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There was no statistically evident difference in the rate of treatment success based on use of a single antihypertensive, for ARBs compared to ACEIs. There were no consistent differential effects of ACEIs vs. ARBs on several potentially important clinical outcomes, including lipid levels, progression to type 2 diabetes mellitus, markers of carbohydrate metabolism/diabetes control, measures of LV mass or function, and progression of renal disease (either based on creatinine, GFR, or proteinuria). Relatively few studies assessed these outcomes over the long term. | A network meta-analysis (which facilitates the inclusion of both direct and indirect comparison trials) to evaluate the incident diabetes in 22 clinical trials of antihypertensive drugs found that ARBs and ACEs are the antihypertensive agents least associated with incident hypertension but did not find a robust difference between the two (Elliott and Meyer, 2007). | No new information. | Three experts judged the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 2: For adult patients with essential hypertension, how do ACEIs and ARBs differ in safety, adverse events, tolerability, persistence, and adherence?
ACEIs have been consistently shown to be associated with slightly greater risk of cough than ARBs. There was no evidence of differences in rates of other commonly reported specific adverse events to quantify. | A RCT comparing telmisartan with ramipril showed that telmisartan resulted in a lower rate of cough (1.1% vs. 4.2%, p <.001) than ramipril (ONTARGET Investigators, 2008). | No new information. | One expert identified a recent RCT with data on cough: Telmisartan (an ARB) had lower rate of cough (1.1% vs 4.2%, p <.001) than ramipril (ONTARGET Investigators, 2008). Three experts judged the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Angioedema was reported only in patients treated with ACEIs; however, because angioedema was rarely explicitly reported in the included studies, it was not possible to estimate its frequency in this population. | A RCT comparing telmisartan to ramipril showed that telmisartan had a lower rate of angioedema than ramipril (0.1% vs. 0.3%, p=.01) (ONTARGET Investigators, 2008). | No new information. | One expert identified a recent RCT with data on angioedema: telmisartan had a lower rate of angioedema than ramipril (0.1% vs 0.3%, p=.01) (ONTARGET Investigators, 2008) One expert did not know if the conclusion was still valid. One expert judged the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
ACEIs and ARBs have similar rates of adherence based on pill counts; this result may not be applicable outside the clinical trial setting. Rates of continuation with therapy appear to be somewhat better with ARBs than with ACEIs; however, due to variability in definitions, limitations inherent in longitudinal cohort studies, and relatively small sample sizes for ARBs, the precise magnitude of this effect is unknown. | No new evidence. | No new information. | Three experts judged the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 3: Are there subgroups of patients based on demographic characteristics (age, racial and ethnic groups, sex), use of other medications concurrently, or comorbidities for which ACEIs or ARBs are more effective, associated with fewer adverse events, or better tolerated?
Evidence does not support conclusions regarding the comparative effectiveness, adverse events, or tolerability of ACEIs and ARBs for any particular patient subgroup. | DIRECT, a randomized controlled trial of the effects of candesartan vs. placebo on incidence and progression of retinopathy in Type 1 diabetics and on progression and regression of retinopathy in Type 2 diabetics showed that it reduced incidence but not progression in Type 1 diabetics (Sjølie, 2008), did not reduce progression in type 2 diabetics, and had a small but significant effect on regression in early disease stages (Chaturvedi, 2008). | 8/29/2006, Losartan (Cozaar), Labeling Revision-Under the “PRECAUTIONS/Drug Interactions” subsection, add Lithium: As with other drugs which affect the excretion of sodium, lithium excretion may be reduced. Therefore, serum lithium levels should be monitored carefully if lithium salts are to be co- administered with angiotensin II receptor antagonists. 8/17/2007, DIOVAN (VALSARTAN) TABLET; ORAL, Labeling Revision- “USE IN PREGNANCY” warning, to update the pregnancy information, including increased risk of injury and death to the developing fetus and birth defects, based on a publication regarding the use of ACE inhibitors during the first trimester of pregnancy. 8/17/2006, ATACAND (CANDESARTAN CILEXETIL), Under “PRECAUTIONS, General,” add Major Surgery/Anesthesia Hypotension may occur during major surgery and anesthesia in patients treated with angiotensin II receptor antagonists, including candesartan, due to blockade of the renin-angiotensin system. Very rarely, hypotension may be severe such that it may warrant the use of intravenous fluids and/or vasopressors. | One expert concludes DIRECT showed slight edge for ARB in diabetic retinopathy (Sjølie, 2008; Chaturvedi, 2008). Three experts judged the conclusion is still valid. | Conclusion is possibly out of date and this portion may need updating, based on new FDA data about possible adverse events.
Are there new data that could inform the key questions that might not be addressed in the conclusions? Additional comments: 1) Meta-analysis suggesting increase in adverse events with combination of ACEI/ARB vs ACEI alone in patients with heart failure (Phillips, 2007). 2) Small case series showed slowing of progressive aortic root dilation in Marfan’s patients on ARB (Brooke, 2008). 3) One expert states: Unaware of any new head-to-head comparisons in the treatment of essential hypertension that would impact these initial conclusions. I am not an expert in this area and it is possible that I may be unaware of some new evidence, but I doubt it. 4) The ONTARGET study (ONTARGET Investigators, 2008), the largest trial comparing ACE-I (ramipril) with ARB (telmisartan) and both with respect to cardiovascular events, demonstrated no difference, again supporting the above conclusions.

Legend: AAA: Abdominal aortic aneurysm; ACEI: Angiotensin converting enzyme inhibitor; ARB: Angiotensin receptor blocker/antagonist; BP: Blood pressure; DIRECT: DIabetic REtinopathy Candesartan Trials; MI: Myocardial infarction; ONTARGET: ONgoing Telmisartan Alone and in combination with Ramipril Global Endpoint Trial; TRANSCEND: Telmisartan Randomized AssessmeNt Study in ACE iNtolerant subjects with cardiovascular Disease

### References

Ahimastos AA, Lawler A, Reid CM, Blombery PA, Kingwell BA. Brief communication: ramipril markedly improves walking ability in patients with peripheral arterial disease: a randomized trial. Ann Intern Med. May 2. 2006;144(9):660-664. [pmid: 16670135].
Al-Mallah MH, Tleyjeh IM, Abdel-Latif AA, Weaver WD. Angiotensin-converting enzyme inhibitors in coronary artery disease and preserved left ventricular systolic function: a systematic review and meta-analysis of randomized controlled trials. J Am Coll Cardiol. Apr 18. 2006;47(8):1576-1583. [pmid: 16630993].
Arima H, Tzourio C, Butcher K, et al. Prior events predict cerebrovascular and coronary outcomes in the PROGRESS trial. Stroke. Jun. 2006;37(6):1497-1502. [pmid: 16627794].
Bogale N, Orn S, James M, McCarroll K, de Luna AB, Dickstein K. Usefulness of either or both left and right bundle branch block at baseline or during follow-up for predicting death in patients following acute myocardial infarction. Am J Cardiol. Mar 1. 2007;99(5):647-650. [pmid: 17317365].
Bosch J, Yusuf S, Gerstein HC, et al. Effect of ramipril on the incidence of diabetes. N Engl J Med. Oct 12. 2006;355(15):1551-1562. [pmid: 16980380].
Chaturvedi N, Porta M, Klein R, et al. Effect of candesartan on prevention (DIRECT-Prevent 1) and progression (DIRECT-Protect 1) of retinopathy in type 1 diabetes: randomised, placebo-controlled trials. Lancet. Oct 18. 2008;372(9647):1394-1402. [pmid: 18823656].
Cooper-Dehoff R, Cohen JD, Bakris GL, et al. Predictors of development of diabetes mellitus in patients with coronary artery disease taking antihypertensive medications (findings from the INternational VErapamil SR-Trandolapril STudy [INVEST]). Am J Cardiol. Oct 1. 2006;98(7):890-894. [pmid: 16996868].
Dagenais GR, Pogue J, Fox K, Simoons ML, Yusuf S. Angiotensin-converting-enzyme inhibitors in stable vascular disease without left ventricular systolic dysfunction or heart failure: a combined analysis of three trials. Lancet. Aug 12. 2006;368(9535):581-588. [pmid: 16905022].
Dart AM, Cameron JD, Gatzka CD, et al. Similar effects of treatment on central and brachial blood pressures in older hypertensive subjects in the Second Australian National Blood Pressure Trial. Hypertension. Jun. 2007;49(6):1242-1247. [pmid: 17470723].
Davis BR, Piller LB, Cutler JA, et al. Role of diuretics in the prevention of heart failure: the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial. Circulation. May 9. 2006;113(18):2201-2210. [pmid: 16651474].
Elliott WJ, Meyer PM. Incident diabetes in clinical trials of antihypertensive drugs: a network meta-analysis. Lancet. Jan 20. 2007;369(9557):201-207. [pmid: 17240286].
Felker GM, Allen LA, Pocock SJ, et al. Red cell distribution width as a novel prognostic marker in heart failure: data from the CHARM Program and the Duke Databank. J Am Coll Cardiol. Jul 3. 2007;50(1):40-47. [pmid: 17601544].
Gerdts E, Wachtell K, Omvik P, et al. Left atrial size and risk of major cardiovascular events during antihypertensive treatment: losartan intervention for endpoint reduction in hypertension trial. Hypertension. Feb. 2007;49(2):311-316. [pmid: 17178978].
Hackam DG, Thiruchelvam D, Redelmeier DA. Angiotensin-converting enzyme inhibitors and aortic rupture: a population-based case-control study. Lancet. Aug 19. 2006;368(9536):659-665. [pmid: 16920471].
Hall AS, Strauss MH. More about the "ARB MI paradox". Heart. Sep. 2007;93(9):1011-1014. [pmid: 17699164].
Hawkins NM, Wang D, McMurray JJ, et al. Prevalence and prognostic implications of electrocardiographic left ventricular hypertrophy in heart failure: evidence from the CHARM programme. Heart. Jan. 2007;93(1):59-64. [pmid: 16952975].
Hood SJ, Taylor KP, Ashby MJ, Brown MJ. The spironolactone, amiloride, losartan, and thiazide (SALT) double-blind crossover trial in patients with low-renin hypertension and elevated aldosterone-renin ratio. Circulation. Jul 17. 2007;116(3):268-275. [pmid: 17606839].
Hou FF, Zhang X, Zhang GH, et al. Efficacy and safety of benazepril for advanced chronic renal insufficiency. N Engl J Med. Jan 12. 2006;354(2):131-140. [pmid: 16407508].
Julius S, Nesbitt SD, Egan BM, et al. Feasibility of treating prehypertension with an angiotensin-receptor blocker. N Engl J Med. Apr 20. 2006;354(16):1685-1697. [pmid: 16537662].
Julius S, Weber MA, Kjeldsen SE, et al. The Valsartan Antihypertensive Long-Term Use Evaluation (VALUE) trial: outcomes in patients receiving monotherapy. Hypertension. Sep. 2006;48(3):385-391. [pmid: 16864741].
Latini R, Masson S, Anand IS, et al. Prognostic value of very low plasma concentrations of troponin T in patients with stable chronic heart failure. Circulation. Sep 11. 2007;116(11):1242-1249. [pmid: 17698733].
Leenen FH, Nwachuku CE, Black HR, et al. Clinical events in high-risk hypertensive patients randomly assigned to calcium channel blocker versus angiotensin-converting enzyme inhibitor in the antihypertensive and lipid-lowering treatment to prevent heart attack trial. Hypertension. Sep. 2006;48(3):374-384. [pmid: 16864749].
Little WC, Zile MR, Klein A, Appleton CP, Kitzman DW, Wesley-Farrington DJ. Effect of losartan and hydrochlorothiazide on exercise tolerance in exertional hypertension and left ventricular diastolic dysfunction. Am J Cardiol. Aug 1. 2006;98(3):383-385. [pmid: 16860028].
Mancini GB, Etminan M, Zhang B, Levesque LE, FitzGerald JM, Brophy JM. Reduction of morbidity and mortality by statins, angiotensin-converting enzyme inhibitors, and angiotensin receptor blockers in patients with chronic obstructive pulmonary disease. J Am Coll Cardiol. Jun 20. 2006;47(12):2554-2560. [pmid: 16781387].
McMurray J, Solomon S, Pieper K, et al. The effect of valsartan, captopril, or both on atherosclerotic events after acute myocardial infarction: an analysis of the Valsartan in Acute Myocardial Infarction Trial (VALIANT). J Am Coll Cardiol. Feb 21. 2006;47(4):726-733. [pmid: 16487836].
Mitchell GF, Dunlap ME, Warnica W, et al. Long-term trandolapril treatment is associated with reduced aortic stiffness: the prevention of events with angiotensin-converting enzyme inhibition hemodynamic substudy. Hypertension. Jun. 2007;49(6):1271-1277. [pmid: 17452505].
Mochizuki S, Dahlof B, Shimizu M, et al. Valsartan in a Japanese population with hypertension and other cardiovascular disease (Jikei Heart Study): a randomised, open-label, blinded endpoint morbidity-mortality study. Lancet. Apr 28. 2007;369(9571):1431-1439. [pmid: 17467513].
Morawietz H, Erbs S, Holtz J, et al. Endothelial Protection, AT1 blockade and Cholesterol-Dependent Oxidative Stress: the EPAS trial. Circulation. Jul 4. 2006;114(1 Suppl):I296-301. [pmid: 16820589].
Okin PM, Devereux RB, Gerdts E, et al. Impact of diabetes mellitus on regression of electrocardiographic left ventricular hypertrophy and the prediction of outcome during antihypertensive therapy: the Losartan Intervention For Endpoint (LIFE) Reduction in Hypertension Study. Circulation. Mar 28. 2006;113(12):1588-1596. [pmid: 16534012].
Okin PM, Devereux RB, Harris KE, et al. Regression of electrocardiographic left ventricular hypertrophy is associated with less hospitalization for heart failure in hypertensive patients. Ann Intern Med. Sep 4. 2007;147(5):311-319. [pmid: 17785486].
Okin PM, Devereux RB, Harris KE, et al. In-treatment resolution or absence of electrocardiographic left ventricular hypertrophy is associated with decreased incidence of new-onset diabetes mellitus in hypertensive patients: the Losartan Intervention for Endpoint Reduction in Hypertension (LIFE) Study. Hypertension. Nov. 2007;50(5):984-990. [pmid: 17893425].
Okin PM, Devereux RB, Nieminen MS, et al. Electrocardiographic strain pattern and prediction of new-onset congestive heart failure in hypertensive patients: the Losartan Intervention for Endpoint Reduction in Hypertension (LIFE) study. Circulation. Jan 3. 2006;113(1):67-73. [pmid: 16365195].
Okin PM, Wachtell K, Devereux RB, et al. Regression of electrocardiographic left ventricular hypertrophy and decreased incidence of new-onset atrial fibrillation in patients with hypertension. JAMA. Sep 13. 2006;296(10):1242-1248. [pmid: 16968848].
Olsson LG, Swedberg K, Ducharme A, et al. Atrial fibrillation and risk of clinical events in chronic heart failure with and without left ventricular systolic dysfunction: results from the Candesartan in Heart failure-Assessment of Reduction in Mortality and morbidity (CHARM) program. J Am Coll Cardiol. May 16. 2006;47(10):1997-2004. [pmid: 16697316].
O'Meara E, Clayton T, McEntegart MB, et al. Clinical correlates and consequences of anemia in a broad spectrum of patients with heart failure: results of the Candesartan in Heart Failure: Assessment of Reduction in Mortality and Morbidity (CHARM) Program. Circulation. Feb 21. 2006;113(7):986-994. [pmid: 16476847].
O'Meara E, Clayton T, McEntegart MB, et al. Sex differences in clinical characteristics and prognosis in a broad spectrum of patients with heart failure: results of the Candesartan in Heart failure: Assessment of Reduction in Mortality and morbidity (CHARM) program. Circulation. Jun 19. 2007;115(24):3111-3120. [pmid: 17562950].
Omland T, Sabatine MS, Jablonski KA, et al. Prognostic value of B-Type natriuretic peptides in patients with stable coronary artery disease: the PEACE Trial. J Am Coll Cardiol. Jul 17. 2007;50(3):205-214. [pmid: 17631211].
Prasad SK, Dargie HJ, Smith GC, et al. Comparison of the dual receptor endothelin antagonist enrasentan with enalapril in asymptomatic left ventricular systolic dysfunction: a cardiovascular magnetic resonance study. Heart. Jun. 2006;92(6):798-803. [pmid: 16339819].
Rahman M, Pressel S, Davis BR, et al. Cardiovascular outcomes in high-risk hypertensive patients stratified by baseline glomerular filtration rate. Ann Intern Med. Feb 7. 2006;144(3):172-180. [pmid: 16461961].
Ridker PM, Danielson E, Rifai N, Glynn RJ. Valsartan, blood pressure reduction, and C-reactive protein: primary report of the Val-MARC trial. Hypertension. Jul. 2006;48(1):73-79. [pmid: 16714425].
Rodriguez-Granillo GA, Vos J, Bruining N, et al. Long-term effect of perindopril on coronary atherosclerosis progression (from the perindopril's prospective effect on coronary atherosclerosis by angiography and intravascular ultrasound evaluation [PERSPECTIVE] study). Am J Cardiol. Jul 15. 2007;100(2):159-163. [pmid: 17631061].
Sabatine MS, Morrow DA, Jablonski KA, et al. Prognostic significance of the Centers for Disease Control/American Heart Association high-sensitivity C-reactive protein cut points for cardiovascular and other outcomes in patients with stable coronary artery disease. Circulation. Mar 27. 2007;115(12):1528-1536. [pmid: 17372173].
Sica DA. The Valsartan Antihypertensive Long-Term Use Evaluation trial: a study in contrasts. Hypertension. Sep. 2006;48(3):362-363. [pmid: 16864742].
Sjolie AK, Klein R, Porta M, et al. Effect of candesartan on progression and regression of retinopathy in type 2 diabetes (DIRECT-Protect 2): a randomised placebo-controlled trial. Lancet. Oct 18. 2008;372(9647):1385-1393. [pmid: 18823658].
Solomon SD, Lin J, Solomon CG, et al. Influence of albuminuria on cardiovascular risk in patients with stable coronary artery disease. Circulation. Dec 4. 2007;116(23):2687-2693. [pmid: 18025537].
Solomon SD, Rice MM, K AJ, et al. Renal function and effectiveness of angiotensin-converting enzyme inhibitor therapy in patients with chronic stable coronary disease in the Prevention of Events with ACE inhibition (PEACE) trial. Circulation. Jul 4. 2006;114(1):26-31. [pmid: 16801465].
Wachtell K, Okin PM, Olsen MH, et al. Regression of electrocardiographic left ventricular hypertrophy during antihypertensive therapy and reduction in sudden cardiac death: the LIFE Study. Circulation. Aug 14. 2007;116(7):700-705. [pmid: 17664372].
Wang JG, Li Y, Franklin SS, Safar M. Prevention of stroke and myocardial infarction by amlodipine and Angiotensin receptor blockers: a quantitative overview. Hypertension. Jul. 2007;50(1):181-188. [pmid: 17502490].
Wang JG, Staessen JA, Li Y, et al. Carotid intima-media thickness and antihypertensive treatment: a meta-analysis of randomized controlled trials. Stroke. Jul. 2006;37(7):1933-1940. [pmid: 16763185].
Weber MA. New opportunities in cardiovascular patient management: a survey of clinical data on the combination of angiotensin-converting enzyme inhibitors and angiotensin receptor blockers. Am J Cardiol. Aug 6. 2007;100(3A):45J-52J. [pmid: 17599439].
Weber MA, Messerli FH. Angiotensin-converting enzyme inhibitors and angioedema: estimating the risk. Hypertension. Jun. 2008;51(6):1465-1467. [pmid: 18413486].

## CER 11. Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults

For this assessment, a limited literature search was conducted for the years 2006–2008. This search included the five generalist journals listed in the Methods and four specialty journals (as recommended by the subject matter experts): Arthritis and Rheumatism; Journal of Rheumatology; British Journal of Rheumatology; and Annals of Rheumaticologic Disease. The search identified 364 titles, of which 57 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of the 57 selected for further review, 26 were abstracted. The remaining articles were rejected because they had already been included in the earlier report or did not include a comparison of interest.

We consulted the project lead, four peer reviewers, and one additional subject matter expert for their assessments. Of these six individuals, three responded. Table 2.9 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.9 CER 11. Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SC EPC
Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | EPC Investigator, 2 OtherExperts | Conclusion from SC EPC
Key Question 1: For patients with rheumatoid arthritis or psoriatic arthritis, do drug therapies differ in their ability to reduce patient-reported symptoms, to slow or limit progression of radiographic joint damage, or to maintain remission?
The data show no differences in radiographic outcomes over 2 years for leflunomide and methotrexate (MTX). One systematic review that included a meta-analysis of two RCTs suggested that higher proportions of patients on MTX than on leflunomide met the American College of Rheumatology(ACR) 20-percent improvement criteria at 1 year but statistical significance was lost at 2 years. | No new evidence. | No new information found. | No opinions provided by experts. | Conclusion is still valid and this portion of the CER does not need updating.
In three studies, patients on etanercept had a faster onset of action than patients on infliximab, although no differences in effectiveness were apparent between the two agents. | No new evidence. | No new information found. | One expert judged this conclusion was still valid with this comment: “New evidence exists—so far only in abstract form and relates to etanercept with respect to rituximab (I think). There is no new evidence for infliximab.” | Conclusion is still valid and this portion of the CER does not need updating.
Adjusted indirect comparisons indicate that anakinra has lower efficacy than anti-Tumor Necrosis Factor (TNF) drugs. | No new evidence (suggested citation was included in previous CER). | No new information found. | One expert judged this conclusion providing a reference in support (Zink, 2005). | Conclusion is still valid and this portion of the CER does not require updating.
One prospective cohort study enrolled a population who failed initial RA treatment. After 12 months, patients on biologic Disease Modifying Antirheumatic Drugs(DMARDs) had almost four times higher odds of achieving functional independence percent and almost two times higher odds of achieving remission than patients on synthetic DMARDs. | No new results found. (Suggested article did not meet the CER's inclusion criteria as it was not a meta-analysis and included studies that were themselves reviewed in the CER). | No new information found. | Two experts agreed this conclusion was still valid with these comments: “New evidence supporting this, perhaps changing estimates slightly, but general conclusions unchanged.” – MSA. “Lots more on remission-more than I can list; see review by Sesin and Bingham, 2005.” | Conclusion is still valid and this portion of the CER does not need updating.
Combination strategies of one or more synthetic DMARDs with corticosteroids have better outcomes than synthetic DMARD monotherapy. | Several articles were found which affect this conclusion. An RCT with 508 subjects combination therapy with MTX+sulfasalazine+prednisone was superior to MTX monotherapy in improvement of functional ability, quality of life and radiographic outcomes (Allaart, 2007). A double-blind RCT with160 patients, cyclosporine had equivocal role in combination with intraarticular betamethasone and MTX; improving ACR20 and ACR-N scores, but not ACR50, ACR70, remission rates, or radiographic changes. (Hetland, 2006; Hetland, 2008). In an unblinded RCT the combination of cyclosporine and leflunomide was better than monotherapy with either alone for ACR50 at 12 months (80% for combination vs. 40% and 42% for cyclosporine and leflunomide respectively, p=0.001), though Disease Activity Score (DAS)28 scores were not significantly different. (Karanikolas 2006). An RCT of 44 patients demonstrated that MTX+intravenous methylprednisone was superior to MTX monotherapy in reducing magnetic resonance imaging (MRI)- detected synovitis and bone edema as well as ACR20/50/70 and remission at 52 weeks (Durez, 2007). | No new information found. | One expert judged this conclusion was still valid, citing an article for support (Hetland, 2008). | Conclusion is possibly out of date and this portion of the CER may need updating due to new studies which may change the strength of the conclusion.
Overall, combination therapy of biologic DMARDs and MTX achieved better clinical response rates than monotherapies. | The review found articles supporting this conclusion for many previously reviewed drugs: infliximab(Smolen, 2006; Smolen 2008), etanercept (Emery, 2008; van der Heijde, 2007) and rituximab (Mease, 2008). No new articles were identified for abatacept or adalimumab. There were several studies of biologics which have not been included in the CER previously. There was one trial of golimumab (an anti-TNF antibody) which improved ACR20 at 16 weeks (Kay, 2008). Two studies of tocilizumab (an IL-6 antagonist) which found a stronger effect for combination therapy with MTX than MTX monotherapy (Maini, 2006 and Genovese 2008). There was one study found of denosumab (a RANKL antagonist) with MTX which improved radiographic outcomes over MTX monotherapy (Cohen, 2008). One study was found regarding psoriatic arthritis, in which combination therapy of Alefacept (a T-cell activation inhibitor) with MTX improved ACR20 at 24 weeks compared to MTX monotherapy (Mease, 2006). | No new information found. | One expert judged this conclusion still valid, stating that there are multiple articles which support this conclusion and citing one (Smolen, 2008). | Conclusion is out of date and this portion of the CER needs updating because of studies on new drugs and new studies of previously reviewed drugs which will not change the general conclusion but will extend it to new drugs and better refine the estimate of benefit.
A combination of etanercept with sulfasalazine did not achieve better outcomes than etanercept monotherapy. | No new evidence. | No new information found. | No opinions provided by experts. | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 2: For patients with rheumatoid arthritis or psoriatic arthritis, do drug therapies differ in their ability to improve functional capacity or quality of life?
Patients on MTX had less improvement in functional status and health-related quality of life than patients taking leflunomide. | No new evidence. | No new information found. | One expert thought this conclusion valid but with this comment: “Personally, data is weak that differences are important.” One expert stated they did not know. | Conclusion is still valid and this portion of the CER does not need updating.
Existing head-to-head evidence (three RCTs) supports no differences in efficacy between MTX and sulfasalazine by ACR 20,DAS, and functional capacity. | No new evidence. | No new information found. | One expert stated that they did not know. | Conclusion is still valid and this portion of the CER does not need updating.
Greater improvements in functional capacity and quality of life were found with combination therapies (adalimumab, infliximab, or etanercept plus MTX) than with MTX alone. | Several new studies were found that supported this conclusion: adalimumab (Kimel, 2008 and Bejarano, 2008.), infliximab (Allaart, 2007). Additionally, one study supported this conclusion for a drug (rituximab) which had not previously been reviewed in by the CER (Mease, 2008). | No new information found. | One expert judged this conclusion still valid, stating: “New evidence exists but I don’t have the references in mind.” | Conclusion is possibly out of date and this portion of the CER may need updating, based on a new study about a previously included drug that had not been studied.
Key Question 3: For patients with rheumatoid arthritis or psoriatic arthritis, do drug therapies differ in harms, tolerability, adherence, or adverse effects?
No differences in tolerability were reported for leflunomide, MTX, and sulfasalazine. Discontinuation rates because of adverse events did not differ among leflunomide, MTX, or sulfasalazine. | No new evidence. | No new information found. | No opinions provided by experts. | Conclusion is still valid and this portion of the CER does not need updating.
Biologic DMARDs were generally well tolerated in efficacy studies. Injection site reactions were substantially higher in patients using anakinra than in patients on adalimumab or etanercept. | No new evidence. | No new information found. | One expert felt that this conclusion was no longer valid, stating: “Higher, yes, but not clear about SUBSTANTIALLY higher.” | Conclusion is possibly out of date and this portion of the CER may need updating, based on diversity of expert opinion.
Combination studies involving two synthetic DMARDs, including sulfasalazine andMTX, vs. one DMARD showed no differences in withdrawal rates because of adverse events. Combination studies including prednisone with one or more DMARDs also had no differences in discontinuation rates between groups. | One article was found supporting this conclusion (Allaart, 2007). | No new information found. | One expert stated that s/he did not know if this conclusion was still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Biologic combination vs. monotherapy: One RCT did not detect any synergistic effects of a combination treatment of etanercept and anakinra compared with etanercept monotherapy. The incidence of serious adverse events, however, was substantially higher with the combination treatment (14.8 percent vs. 2.5 percent; P = NR). | No new evidence. | No new information found. | One expert felt that this conclusion was still valid, stating: “Another study showed 7.3% serious infections vs. 4.3% (not sure of numbers but something like that) and also found that abatacept plus Tumor Necrosis Factor Inhibitors is associated with more serious infections.” | Conclusion is possibly out of date and this portion of the CER may need updating based on diversity of reviewer opinion: one expert recalled studies that were not found on our targeted search.
A combination treatment of two biologicDMARDs can lead to substantiallyhigher rates of severe adverse events than biologic DMARD monotherapy. The evidence, is limited to combinations of anakinra plus etanercept and abatacept plus anakinra, adalimumab, etanercept, or infliximab | No new evidence. | No new information found. | No opinions provided by experts. | Conclusion is still valid and this portion of the CER does not need updating.
No differences in adverse events were found between combinations of biologic and synthetic. | No new evidence. | No new information found. | One expert felt this conclusion was invalid, stating: “I'm not sure if this is mis-stated. Combination of biologics have a much higher rate of adverse events-i.e., infections-than combinations of synthetic DMARDS. This evidence was already present at the time the review was written.” One expert did not know. | This conclusion should possibly be reworded to make clear exactly what comparisons are being made.
In general, no statistically significant differences in adverse events existed between combinations of biologic and synthetic DMARDs and synthetic DMARD monotherapy. Studies, however, were too small to assess reliably differences in rare but severe adverse events. An exception was a study with high-dose infliximab plus MTX therapy, which led to a statistically significantly higher rate of serious infections than MTX monotherapy. | Three clinical trials which did not find statistically significant differences (Allaart, 2007; Durez, 2007; Kay, 2008). The suggested article is a review from 2004 which was not a meta-analysis and did not meet criteria of the original CER (Khanna, 2004). | No new information found. | One reviewer felt this conclusion was out of date, stating: “This is true for clinical trials, but indirect comparisons and cohort studies show greater incidence of serious adverse events, mostly infections with biologic therapies.” Another reviewer felt this conclusion was still valid, adding that he thought this was also true of CHF and providing a reference (Khanna, 2004). | Conclusion is probably out of date and this portion of the CER may need updating based on new data and diversity of expert opinion that might change the conclusion.
Key Question 4: What are the comparative benefits and harms of drug therapies for rheumatoid arthritis and psoriatic arthritis in subgroups of patients based on stage of disease, history of prior therapy, demographics, concomitant therapies, or comorbidities?
No comparative evidence exists on psoriatic arthritis (PsA) for any drugs. | No new evidence. | No new information found. | One reviewer felt this conclusion was still valid, stating: “There is some weak evidence from cohort data that there are no differences. Not important enough to modify review I think” and provided a reference (Gratacos 2007). One reviewer did not know. | Conclusion is still valid and this portion of the CER does not need updating.
For RA the strength of evidence for age, sex, and comorbidities is very weak. | No new evidence. | No new information found. | No opinions provided by experts. | Conclusion is still valid and this portion of the CER does not need updating.
A combination of either adalimumab plus MTX or infliximab plus methotrexate in patients with early, aggressive RA who were methotrexate naive led to better clinical and radiographic outcomes than MTX monotherapy. | Two trials supporting this conclusion for infliximab were reported (Goekoop-Ruiterman, 2007; Allaart 2007) and two for adalimumab (Bejarano, 2008; Kimel, 2008). | No new information found. | One reviewer felt this conclusion was still valid, and noted that he though this evidence also existed for adalimumab. | Conclusion is still valid and this portion of the CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? One expert comments that some of our team members were involved in updating a lit scan (from 7/06 through 12/17/07) for Targeted Immune Modulators. This scan included 5 additional RCTS for rheumatoid arthritis, but only one head to head trial (DeFilippis LA et al etanercept vs. infliximab, N=32). There were 3 psoriatic arthritis studies but they were compared with placebo. One expert comments that most of the new data relates to the use of other biologic therapies. The review will probably need to be updated in the near future for agents such as Rituximab, abatacept, and the new products currently being evaluated for approval. Other findings from the targeted literature search: Use of glucocorticoids: - Intra-articular glucocorticoids in combination with MTX were better than MTX alone, at 52 weeks: ACR20 85% vs. 68% (p=0.02) ACR-N 80% vs. 54.5% (p=0.025); HAQ 0.3 vs. 0.4 (p<0.001); DAS28 not significant. Larsen score not significant. (Hetland 2006) - MTX+infliximab superior to MTX+intravenous methylprednisone for reducing MRI-detected synovitis and bone edema. They had equivalent effects on ACR20,50,70 and remission at 52 weeks. (Durez 2007). Risk of Acute Myocardial Infarction (AMI) - A nested case-control analysis with cohort of 107,908 subjects found synthetic DMARDs (including MTX) were associated with reduced risk of AMI (RR 0.8). Glucocorticoids had increased risk. Biologic DMARDs had no effect (Suissa, 2006). Step up vs. parallel therapy (addresses question in initial CER, page 7) - Step up therapy (sulfasalazine, MTX, hydroxychloroquine) equally efficacious to parallel therapy in early rheumatoid arthritis (Saunders, 2008). - Parallel therapy (sulfasalazine, MTX, prednisone) had faster onset then step up therapy (Allaart, 2007; Goekoop-Ruiterm, 2008). - Parallel therapy (sulfasalazine, MTX, hydroxychloroquine, prednisolone) better than step up therapy (Makinen, 2007). Therapies not included in initial CER: -Tacrolimus (T cell inhibitor) superior to mizoribine (T cell blocker) with 28 week ACR20 of 48% compared to 10% (Kawai, 2006). - A 2 year RCT found ACR50 response in 40% of patients on Doxycycline+MTX compared to 12% patients on MTX alone (O'Dell, 2006).

Legend: DMARD: disease-modifying antirheumatic drug; MTX: methotrexate; anti-TNF: anti-Tumor Necrosis Factor; ACR20/50/70: American College of Rheumatology 20/50/70-percent improvement criteria; DAS28: Disease Activity Score shortform;

### References

Allaart CF, Breedveld FC, Dijkmans BAC. Treatment of recent-onset rheumatoid arthritis: lessons from the BeSt study. J Rheumatol Suppl. 2007;80:25-33. [pmid: 17985420].
Bejarano V, Quinn M, Conaghan PG, et al. Effect of the early use of the anti-tumor necrosis factor adalimumab on the prevention of job loss in patients with early rheumatoid arthritis. Arthritis Rheum. 2008;59(10):1467-1474. [pmid: 18821658].
Cohen SB, Dore RK, Lane NE, et al. Denosumab treatment effects on structural damage, bone mineral density, and bone turnover in rheumatoid arthritis: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, phase II clinical trial. Arthritis Rheum. 2008;58(5):1299-1309. [pmid: 18438830].
Durez P, Malghem J, Nzeusseu Toukap A, et al. Treatment of early rheumatoid arthritis: a randomized magnetic resonance imaging study comparing the effects of methotrexate alone, methotrexate in combination with infliximab, and methotrexate in combination with intravenous pulse methylprednisolone. Arthritis Rheum. 2007;56(12):3919-3927. [pmid: 18050189].
Emery P, Breedveld FC, Hall S, et al. Comparison of methotrexate monotherapy with a combination of methotrexate and etanercept in active, early, moderate to severe rheumatoid arthritis (COMET): a randomised, double-blind, parallel treatment trial. Lancet. 2008;372(9636):375-382. [pmid: 18635256].
Genovese MC, McKay JD, Nasonov EL, et al. Interleukin-6 receptor inhibition with tocilizumab reduces disease activity in rheumatoid arthritis with inadequate response to disease-modifying antirheumatic drugs: the tocilizumab in combination with traditional disease-modifying antirheumatic drug therapy study. Arthritis Rheum. 2008;58(10):2968-2980. [pmid: 18821691].
Goekoop-Ruiterman YPM, de Vries-Bouwstra JK, Allaart CF, et al. Comparison of treatment strategies in early rheumatoid arthritis: a randomized trial. Ann Intern Med. 2007;146(6):406-415. [pmid: 17371885].
Gratacós J, Casado E, Real J, Torre-Alonso JC. Prediction of major clinical response (ACR50) to infliximab in psoriatic arthritis refractory to methotrexate. Ann Rheum Dis. 2007;66(4):493-497. [pmid: 17179176].
Hetland ML, Stengaard-Pedersen K, Junker P, et al. Combination treatment with methotrexate, cyclosporine, and intraarticular betamethasone compared with methotrexate and intraarticular betamethasone in early active rheumatoid arthritis: an investigator-initiated, multicenter, randomized, double-blind, parallel-group, placebo-controlled study. Arthritis Rheum. 2006;54(5):1401-1409. [pmid: 16645967].
Hetland ML, Stengaard-Pedersen K, Junker P, et al. Aggressive combination therapy with intra-articular glucocorticoid injections and conventional disease-modifying anti-rheumatic drugs in early rheumatoid arthritis: second-year clinical and radiographic results from the CIMESTRA study. Ann Rheum Dis. 2008;67(6):815-822. [pmid: 17878209].
Karanikolas G, Charalambopoulos D, Andrianakos A, Antoniades C, Katsilambros N. Combination of cyclosporine and leflunomide versus single therapy in severe rheumatoid arthritis. J Rheumatol. 2006;33(3):486-489. [pmid: 16511917].
Kawai S, Hashimoto H, Kondo H, Murayama T, Kiuchi T, Abe T. Comparison of tacrolimus and mizoribine in a randomized, double-blind controlled study in patients with rheumatoid arthritis. J Rheumatol. Nov. 2006;33(11):2153-2161. [pmid: 16960930].
Kay J, Matteson EL, Dasgupta B, et al. Golimumab in patients with active rheumatoid arthritis despite treatment with methotrexate: a randomized, double-blind, placebo-controlled, dose-ranging study. Arthritis Rheum. 2008;58(4):964-975. [pmid: 18383539].
Khanna D, McMahon M, Furst DE. Anti-tumor necrosis factor alpha therapy and heart failure: what have we learned and where do we go from here?. Arthritis Rheum. 2004;50(4):1040-1050. [pmid: 15077286].
Kimel M, Cifaldi M, Chen N, Revicki D. Adalimumab plus methotrexate improved SF-36 scores and reduced the effect of rheumatoid arthritis (RA) on work activity for patients with early RA. J Rheumatol. 2008;35(2):206-215. [pmid: 18085743].
Maini RN, Taylor PC, Szechinski J, et al. Double-blind randomized controlled clinical trial of the interleukin-6 receptor antagonist, tocilizumab, in European patients with rheumatoid arthritis who had an incomplete response to methotrexate. Arthritis Rheum. 2006;54(9):2817-2829. [pmid: 16947782].
Makinen H, Kautiainen H, Hannonen P, et al. Sustained remission and reduced radiographic progression with combination disease modifying antirheumatic drugs in early rheumatoid arthritis. J Rheumatol. Feb. 2007;34(2):316-321. [pmid: 17183623].
Mease PJ, Gladman DD, Keystone EC. Alefacept in Psoriatic Arthritis Study G. Alefacept in combination with methotrexate for the treatment of psoriatic arthritis: results of a randomized, double-blind, placebo-controlled study. Arthritis Rheum. 2006;54(5):1638-1645. [pmid: 16646026].
Mease PJ, Revicki DA, Szechinski J, et al. Improved health-related quality of life for patients with active rheumatoid arthritis receiving rituximab: Results of the Dose-Ranging Assessment: International Clinical Evaluation of Rituximab in Rheumatoid Arthritis (DANCER) Trial. J Rheumatol. 2008;35(1):20-30. [pmid: 18050385].
O'Dell JR, Elliott JR, Mallek JA, et al. Treatment of early seropositive rheumatoid arthritis: doxycycline plus methotrexate versus methotrexate alone. Arthritis Rheum. Feb. 2006;54(2):621-627. [pmid: 16447240].
Saunders SA, Capell HA, Stirling A, Vallance R, Kincaid W, McMahon AD, Porter DR. Triple therapy in early active rheumatoid arthritis: a randomized, single-blind, controlled trial comparing step-up and parallel treatment strategies. Arthritis Rheum. 2008. May. 58(5):1310-7. [pmid: 18438851].
Sesin CA, Bingham CO. Remission in rheumatoid arthritis: wishful thinking or clinical reality?. Semin Arthritis Rheum. 2005;35(3):185-196. [pmid: 16325659].
Smolen JS, Han C, van der Heijde Dse M, et al. Radiographic changes in rheumatoid arthritis patients attaining different disease activity states with methotrexate monotherapy and infliximab plus methotrexate: the impacts of remission and TNF-blockade. Ann Rheum Dis. 2008.
Smolen JS, Van Der Heijde Dse MFM, St Clair EW, et al. Predictors of joint damage in patients with early rheumatoid arthritis treated with high-dose methotrexate with or without concomitant infliximab: results from the ASPIRE trial. Arthritis Rheum. 2006;54(3):702-710. [pmid: 16508926].
Suissa S, Bernatsky S, Hudson M. Antirheumatic drug use and the risk of acute myocardial infarction. Arthritis Rheum. Aug 15. 2006;55(4):531-536. [pmid: 16874796].
van der Heijde Dse, Klareskog L, Rodriguez-Valverde V, et al. Comparison of etanercept and methotrexate, alone and combined, in the treatment of rheumatoid arthritis: two-year clinical and radiographic results from the TEMPO study, a double-blind, randomized trial. Arthritis Rheum. 2006;54(4):1063-1074. [pmid: 16572441].
Zink A, Listing J, Kary S, et al. Treatment continuation in patients receiving biological agents or conventional DMARD therapy. Ann Rheum Dis. 2005;64(9):1274-1279. [pmid: 15708884].

## CER 12. Comparative Effectiveness of Treatments to Prevent Fractures in Men and Women with Low Bone Density or Osteoporosis

For this assessment, a limited literature search was conducted for the years 2005–2008. This search included the five generalist journals listed in the Methods and four specialty journals (as recommended by the subject matter experts): Bone; Journal of Bone Mineral Research; Osteoporosis International; and Endocrine Reviews. The search identified 549 titles, of which 160 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of the 160 selected for further review, 42 were abstracted into a table. The remaining articles were rejected because they had already been included in the earlier report or did not include a comparison of interest.

We consulted the project lead, four members of the TEP, and one of the peer reviewers for their assessment. Of these six individuals, four responded.

Table 2.10 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.10 CER 12. Comparative Effectiveness of Treatments to Prevent Fractures in Men and Women with Low Bone Density or Osteoporosis: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SC EPC
Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | EPC Investigator, 2 TEP Members, 1 Other Expert | Conclusion from SC EPC
Key Question 1: What are the comparative benefits in fracture reduction among and also within the following treatments for low bone density: * Bisphosphonate medications, specifically alendronate, risedronate, etidronate, ibandronate, pamidronate, and zoledronic acid. * Calcitonin. * Calcium. * Estrogen for women. * Parathyroid hormone (PTH). * Selective estrogen receptor modulators (SERMs), specifically raloxifene and tamoxifen. * Testosterone for men. * Vitamin D. * Combinations of above. * Exercise in comparison to above agents.
There is good evidence that alendronate, etidronate, ibandronate, risedronate, calcitonin, 1-34 PTH, and raloxifene prevent vertebral fractures. | No new evidence. | No new information. | Four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There is good evidence that risedronate and alendronate prevent both nonvertebral and hip fractures. | Pooled analysis of 8 RCTs found dose response of annual cumulative exposure to oral ibandronate and decrease in non-vertebral fracture (Cranney, 2008). | No new information. | Four experts agreed this conclusion is still valid. | Conclusion is possibly out of date and this portion of the CER may need updating due to addition of ibandronate.
There is good evidence that zoledronic acid prevents vertebral and nonvertebral fractures and fair evidence that it prevents hip fractures. | Once-a-year intravenous (iv) zoledronic acid prevented vertebral and non-vertebral fractures in post-menopausal women as well as new hip fractures in hip fracture patients in the HORIZON trial (Black, 2007). | No new information. | Three experts agreed this conclusion is still valid. One expert referred to HORIZON trial. | Conclusion is still valid and this portion of the CER does not need updating.
There is evidence from one RCT that 1-34 PTH prevents nonvertebral fractures. | Evidence from a meta-analysis that 1-34 PTH alone or in combination with bisphosphonates prevents nonvertebral fractures (Vestergard, 2007). | No new information. | Four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There is good evidence that estrogen is associated w/a reduced incidence of vertebral, nonvertebral, and hip fractures. | No new evidence. | No new information. | Four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There are no data from RCTs on the effect of testosterone on prevention of fractures. | No new evidence. | No new information. | Four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There is good evidence that there is no difference between calcium alone and placebo in preventing vertebral, nonvertebral, hip, and wrist fractures in postmenopausal women. | Meta-analysis of 17 trials showed both calcium alone and calcium + vitamin D reduced incidence of fractures of all types (Tang, 2007). | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is possibly out of date and this portion of the CER may need updating. The new meta-analysis should be assessed for quality, inclusion criteria, etc.
Vitamin D has varying effects on fracture prevention, depending on dose, analogs, and population. | No new evidence. | No new information. | Four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Based on limited data from head-to-head trials, superiority for the prevention of fractures has not been demonstrated for any agent within the bisphosphonate class. | A study comparing etidronate with alendronate and risedronate found no difference in preventing first incidence of any fracture (Mamdani, 2007) Studies purporting to show superiority of one agent over others were equivocal. | No new information. | Four experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Based on limited data from head-to-head trials, superiority for the prevention of vertebral fractures has not been demonstrated for bisphosphonates in comparison with calcitonin, calcium, or raloxifene. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. One expert questions existence of head-to-head comparisons of calcitonin with other agents for fracture prevention. | Conclusion is still valid and this portion of the CER does not need updating.
Based on six head-to-head RCTs, there was no difference in fracture incidence between bisphosphonates and estrogen. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? SC-EPC Literature Search – A RCT comparing alendronate with teriparatide for the treatment of glucocorticoid-induced osteoporosis found that fewer new vertebral fractures occurred in the teriparatide group than in the alendronate group (0.6% vs. 6.1%, P = 0.004); the incidence of nonvertebral fractures was similar in the two groups (5.6% vs. 3.7%, P = 0.36) (Saag, 2007). A RCT compared the use of risedronate, 75 mg twice monthly, with that of daily risedronate (n=1229 postmenopausal women) on the secondary outcome of new vertebral fractures. At 1 year follow-up, the incidence of new fractures was the same in both groups (1%) (Delmas, 2008). 1 RCT and pooled data from 2 other RCTs found Strontium ranelate prevents vertebral fractures; 2 RCTs found strontium ranelate prevents nonvertebral fractures, including hip. This drug is not FDA-approved for osteoporosis.
Key Question 2: How does fracture reduction resulting from treatments vary between individuals with different risks for fracture as determined by bone mineral density (borderline/low/severe), prior fractures (prevention vs. treatment), age, gender, glucocorticoid use, and other factors (e.g., community dwelling vs. institutionalized, vitamin D deficient vs. not)?
Alendronate, etidronate, ibandronate, risedronate, teriparatide, & raloxifene reduce the risk of fractures among high-risk groups, including postmenopausal women w/osteoporosis. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating
Calcitonin has been demonstrated to reduce the risk of fracture among postmenopausal women. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Raloxifene prevents fractures in postmenopausal women at low risk for fracture. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
The effect of estrogen on fracture prevention for women at low risk is uncertain. | No new evidence. | No new information. | Two experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Calcitonin, risedronate, and teriparatide reduce the risk of fracture among men. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
In subjects treated with glucocorticoids, fracture risk reduction was demonstrated for risedronate and alendronate. | A RCT comparing alendronate with teriparatide for the treatment of glucocorticoid-induced osteoporosis found that fewer new vertebral fractures occurred in the teriparatide group than in the alendronate group (0.6% vs. 6.1%, P = 0.004); the incidence of nonvertebral fractures was similar in the two groups (5.6% vs. 3.7%, P = 0.36) (Saag, 2007). | No new information | Three experts agreed this conclusion is still valid. One expert cited a head- to-head comparison of alendronate and teriparatide (Saag, 2007). | Conclusion is still valid and this portion of the CER does not need updating.
There is good evidence that tamoxifen does not prevent fractures among women at risk for breast cancer. | No new evidence. | No new information. | Three experts said they cannot assess whether the conclusion remains valid. | Conclusion is still valid and this portion of the CER does not need updating.
Reduction in fracture risk for subjects treated with alendronate, risedronate, or vitamin D has been demonstrated in populations at increased risk for fracture due to conditions that increase the risk of falling, including stroke with hemiplegia, Alzheimer's disease, and Parkinson's disease. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? SC-EPC Literature Search – One RCT found 1-34 PTH prevents spinal and other clinical fractures in women with severely reduced renal function (Miller, 2007). One RCT found alendronate prevents vertebral, hip, and wrist fractures among postmenopausal women with osteoporosis across all age groups; risk reduction was greater in older women and in women at higher risk for fracture (Hochberg, 2005). One RCT found alendronate more effective in postmenopausal women (at low, medium, and high risk for fracture) with elevated bone turnover (Bauer, 2006). One RCT found raloxifene prevention of vertebral fractures in postmenopausal women was not affected by age, smoking status, physical activity, prior fracture history, diabetes, previous use of HRT or thyroid hormone, use of statins, weight loss, BMI, or fracture-specific summary risk score (Ensrud, 2008). Prevention of fractures in women with severe osteoporosis by alendronate, risedronate, or raloxifene was independent of BMI, follow-up duration, number of prior fractures, treatment modality, use of calcium/vitamin D, and compliance (Adami, 2008).
Key Question 3: What are the adherence and persistence to medications for the treatment and prevention of osteoporosis, the factors that affect adherence and persistence, and the effects of adherence and persistence on the risk of fractures?
Only 10 fracture trials reported rates of adherence to therapy. Five trials of calcium reported low rates of adherence. In two studies of daily oral bisphosphonates, more than 80 percent of patients took at least 70 percent of the drug. The other three trials reported high rates of adherence with risedronate therapy. | No new evidence. | No new information. | One expert agreed this conclusion is still valid. One expert did not know. One expert stated “there may be new compliance trials that I do not know about.” | Conclusion is still valid and this portion of the CER does not need updating.
There is evidence from 10 observational studies that real world adherence to therapy with alendronate, etidronate, risedronate, calcitonin, hormone replacement therapy (HRT), raloxifene, calcium, and vitamin D is poor among many postmenopausal women with osteoporosis. | No new evidence. | No new information. | Two experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There is evidence from one observational study that adherence to therapy with alendronate and risedronate is poor in many chronic glucocorticoid users. | No new evidence. | No new information. | Two experts agreed the conclusion is still valid. One expert said that the conclusion is probably still valid, but does not know. | Conclusion is still valid and this portion of the CER does not need updating.
There is evidence from 12 observational studies that persistence with therapy with alendronate, etidronate, risedronate, calcitonin, HRT, raloxifene, calcium, and vitamin D is poor in many men and postmenopausal women with osteoporosis. | No new evidence. | No new information. | Two experts agreed the conclusion is still valid. One expert noted the conclusion is probably still valid but does not know | Conclusion is still valid and this portion of the CER does not need updating.
Based on evidence from observational studies, factors that affect adherence and persistence w/medications include side effects of medications, absence of symptoms related to the underlying disease, comorbid conditions, ethnicity, socioeconomic status, & dosing regimens. Weekly users had higher persistence & adherence rates than daily users. | No new evidence. | 4/22/08 New Dosage Regimen for ACTONEL (RISEDRONATE SODIUM) -approve the use of Actonel (risedronate sodium) 150 mg tablets as a once monthly dose to treat Postmenopausal Osteoporosis (PMO) (S-030). | Two experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
There is evidence from one RCT that postmenopausal women who are nonadherent to treatment with calcium have a higher risk of fracture than women who are adherent to therapy. There is evidence from RCTs and observational studies that postmenopausal women who are nonadherent to treatment with alendronate, risedronate, HRT, calcium, or calcitonin have a higher risk of fracture than women who are adherent to therapy. There is evidence from one observational study that postmenopausal women w/osteoporosis who are nonpersistent w/alendronate and risedronate therapy have a higher risk of fracture than women persistent w/these medications. | An observational study showed that postmenopausal women who had poorer compliance with alendronate, risedronate, or raloxifene had an increased risk of fracture (Adami, 2006); however another observational study of women with severe osteoporosis found no association (Adami, 2008). One randomized controlled trial showed that postmenopausal women who persist with alendronate after 5 years prior treatment have lower risk of clinical vertebral fractures (Black, 2006); and another randomized controlled trial showed that persistence with risedronate results in lower risk for new vertebral fractures (Watts, 2008). Evidence from one RCT that lack of persistence with raloxifene after 4 years did not affect overall risk of nonvertebral fracture except among women at high risk (prevalent vertebral fracture) (Siris, 2005). | No new information. | One expert agreed the conclusion is still valid. One expert responded that the conclusion is probably still valid but does not know. One expert said “Do Not Know - Not sure if there are new compliance trials.” | Conclusion is still valid and this portion of the CER does not need updating.
Key Question 4: What are the short- and long-term harms (adverse effects) of the above therapies, and do these vary by any specific subpopulations?
There is good evidence that there are no differences in the rates of serious cardiac events among bisphosphonates, calcium, vitamin D, calcitonin, PTH, and placebo. | No new evidence. | No new information. | Three experts referred to findings below regarding atrial fibrillation (AF). | Conclusion is still valid and this portion of the CER does not need updating.
A significant increase in the risk of AF for zoledronic acid relative to placebo has been reported in one large RCT but not in another. A trend toward increased risk for alendronate relative to placebo has been reported in a single large RCT. | One population-based case control study in Denmark found no greater “ever use” of bisphosphonates among AF patients (Sorensen, 2008) but a population-based case control study of women in the US did find increased ever use of alendronate (Heckbert, 2008). | No new information. | One expert agreed the conclusion is still valid. One expert cites the HORIZON trial, which showed more episodes of serious AF in those treated with zoledronic acid than placebo, although mechanism not clear [Note: this study was included in the original CER and it did not show a difference in serious AF (Lyles, 2007)]. One expert cites the same 2 case-controlled studies (by Sorensen (2008) and by Heckbert (2008) as found in the SCEPC literature search. One expert cites an increased risk of serious AF with some bisphosphonates (same references as above). One expert notes that observational case- control studies have reported conflicting data for alendronate | Conclusion is possibly out of date and this portion of the CER may need updating due to new evidence and difference in expert opinion.
Relative to placebo, Raloxifene has an increased pooled risk for pulmonary embolism (PE), thromboembolic events, and mild cardiac events (including chest pain, palpitations, tachycardia, and vasodilation). Relative to placebo, the risk of PE for tamoxifen was elevated in one trial; the risk of thromboembolic events did not differ in this trial. | One randomized controlled trial of bazedoxifene vs. raloxifene among healthy postmenopausal women found an increased risk of vasodilation, leg cramps, and venous thromboembolism for both (Silverman, 2008). | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
In three placebo-controlled trials of estrogen that reported cerebrovascular accident, estrogen participants had higher odds than did participants who took a placebo. In the two trials that compared an estrogen-progestin combination with placebo, the combination participants had greater odds of stroke than did placebo patients. When four estrogen studies reporting thromboembolic events were pooled, estrogen participants had greater odds of reporting them than did placebo participants. Similar results were found when three studies comparing an estrogen-progestin combination with placebo were pooled. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Esophageal ulcerations were reported in trials of all the bisphosphonates except zoledronic acid. The only significant difference from placebo was found in one trial in which etidronate participants had higher odds of esophageal ulcers. | No new evidence. | No new information. | Three experts agreed this conclusion is still valid. One expert did not know if the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Perforations, ulcerations, and bleeds (PUBs) were reported in trials of all the bisphosphonates except zoledronic acid. Etidronate participants had higher odds of PUBs than did placebo participants in three pooled studies. In two pooled trials of oral daily ibandronate, treated participants had lower odds of PUBs than did placebo participants. | No new evidence. | No new information. | Three experts agreed the conclusion is still valid. One expert responded the conclusion is probably still valid but did not know. | Conclusion is still valid and this portion of the CER does not need updating
We categorized conditions such as acid reflux, esophageal irritation, nausea, vomiting, and heartburn as “mild upper gastrointestinal (GI) events.” Etidronate users had showed greater odds than for placebo participants. Pooled trials of pamidronate also showed greater odds for drug users than for placebo. Our pooled analyses found no difference between alendronate, ibandronate, risedronate, or zoledronic acid and placebo regarding mild upper GI events. | One study of postmenopausal women found 1-34 PTH increased risk for nausea (Greenspan, 2007). | No new information. | Three experts agreed the conclusion is still valid. One expert responded that the conclusion is probably still valid but did not know. | Conclusion is still valid and this portion of the CER does not need updating.
In contrast, alendronate participants had higher odds of mild upper GI events than did etidronate participants in three pooled head-to-head trials. Alendronate participants also had higher odds of mild upper GI events in four head-to-head trials vs. calcitonin and four head-to-head trials vs. estrogen. Etidronate participants had higher odds of mild upper GI events in three head-to-head trials vs. estrogen. | A head-to-head comparison of raloxifene vs. alendronate found that diarrhea, nausea, and the need for a colonoscopy were greater in the alendronate group (Recker., 2007). | No new information. | Three experts agreed the conclusion is still valid. One expert responded that the conclusion is probably still valid but did not know. | Conclusion is still valid and this portion of the CER does not need updating.
Risedronate participants had lower odds of musculoskeletal events than did placebo participants in nine pooled trials. In three pooled trials, zoledronic acid participants had higher odds of these events than did placebo participants. In two head-to-head trials,259, 354 alendronate participants had greater odds of these events than did participants taking PTH. | No new evidence. | FDA Safety Alert (1/7/08) “Highlight the possibility of severe and sometimes incapacitating bone, joint, and/or muscle (musculoskeletal) pain in patients taking bisphosphonates” i.e. Alendronate, Risedronate, Etidronate, Ibandronate, Pamidronate, and Zoledronic Acid. | Two experts agreed the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
In five pooled trials of estrogen vs. placebo, estrogen participants had lower odds of breast cancer. Conversely, in three pooled studies of estrogen-progestin combination vs. placebo, treatment participants had higher odds of breast cancer. | No new evidence. | No new information. | Two experts agreed the conclusion is still valid. One expert was not sure whether the conclusion is still valid. One expert responded that the conclusion is probably still valid but did not know. | Conclusion is still valid and this portion of the CER does not need updating..
One estrogen-progestin study showed that treated participants had lower odds of colon cancer than did placebo participants. | No new evidence. | No new information. | Two experts agreed the conclusion is still valid. One expert responded that the conclusion is probably still valid but did not know. | Conclusion is still valid and this portion of the CER does not need updating.
In three pooled studies of tamoxifen vs. placebo, tamoxifen participants had lower odds of breast cancer. Differences between raloxifene and placebo were not significant. | No new evidence. | Raloxifene is now FDA-approved for breast cancer prevention. | One expert agreed the conclusion is still valid. One expert was not sure if the conclusion is still valid. One expert noted that raloxifene is now FDA-approved for breast cancer prevention. | Conclusion is out of date and this portion of the CER needs updating due to raloxifene being approved for breast cancer prevention.
Estrogen participants had more gynecological problems (such as uterine bleeding) than placebo participants. The same was true for users of estrogen-progestin combination in three pooled trials. In three pooled trials, tamoxifen participants had greater odds of gynecological problems than did placebo patients. | No new evidence. | No new information. | Two experts agreed the conclusion is, still valid. One expert was not sure if the conclusion is still valid. One expert agreed that the conclusion is probably still valid but did not know. | Conclusion is still valid and this portion of the CER does not need updating.
Osteosarcoma was reported in only one study, a head-to-head trial of raloxifene vs. tamoxifen; differences between groups were not significant. | One case report described identification of osteosarcoma in the postmortem of a postmenopausal woman who had been taking PTH for osteoporosis and who died of cancer (Harper et al., 2007). | FDA Safety Alert (7/29/08) reported increased incidence of osteosarcoma in rats given teriparatide. | One expert agreed the conclusion is still valid. One expert responded that the conclusion is no longer valid: One reported case of osteosarcoma in human taking PTH – unclear if related to PTH One expert did not know. | Conclusion is possibly out of date and this portion of the CER may need updating due to new evidence and difference in expert opinion.
There are no data from osteoporosis trials that describe an association between bisphosphonates and the development of osteonecrosis. In case reports and case series articles, we found many cases of osteonecrosis of the jaw in cancer patients taking intravenous bisphosphonates. Cases involved pamidronate, zoledronic acid, and alendronate. | No new evidence. | No new information. | Two experts judge the conclusion is still valid. One expert states that data from Horizon trial provides info on osteonecrosis of the jaw. This trial was included in the original CER. There was one case in the placebo group and one in the treatment group – both cases resolved with surgery. | Conclusion is still valid and this portion of the CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? SC-EPC Literature Search – One RCT of 1–34 PTH found an increased risk for hypercalciuria and hypercalcemia (Greenspan, 2007); another RCT in women with renal impairment found a decrease in mean glomerular filtration rate (Miller, 2007). 12/11/07 AREDIA (PAMIDRONATE DISODIUM) Labeling Revision - Add Warning: Deterioration in Renal Function Calcium+Vitamin D increased the risk of renal calculi among postmenopausal women at low risk for osteoporosis (Jackson, 2006). 3/20/08 Zometa (ZOLEDRONIC ACID) Patient Population Altered - approve the use of Zometa in pediatric patients with severe osteogenesis imperfecta.

Legend: AF: atrial fibrillation; PE: pulmonary embolism; PTH: parathyroid hormone; PUBs: perforations, ulcerations, and bleeds; SERM: selective estrogen receptor modulator.

### References

Adami S. Protelos: nonvertebral and hip antifracture efficacy in postmenopausal osteoporosis. Bone. 2006;38(2 Suppl 1):23-7. [pmid: 16434247].
Adami S, Isaia G, Luisetto G, Minisola S, Sinigaglia L, Gentilella R, Agnusdei D, Iori N, Nuti R. Fracture incidence and characterization in patients on osteoporosis treatment: the ICARO study. J Bone Miner Res. 2006;21(10):1565-70. [pmid: 16995811].
Adami S, Isaia G, Luisetto G, Minisola S, Sinigaglia L, Silvestri S, Agnusdei D, Gentilella R, Nuti R. Osteoporosis treatment and fracture incidence: the ICARO longitudinal study. Osteoporos Int. 2008;19(8):1219-1223. [pmid: 18286217].
Barrett-Connor E, Mosca L, Collins P, Geiger MJ, Grady D, Kornitzer M, McNabb MA, Wenger NK. Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med. 2006;355(2):125-37. [pmid: 16837676].
Bauer DC, Garnero P, Hochberg MC, Santora A, Delmas P, Ewing SK, Black DM. Pretreatment levels of bone turnover and the antifracture efficacy of alendronate: the fracture intervention trial. J Bone Miner Res. 2006;21(2):292-9. [pmid: 16418785].
Black DM, Delmas PD, Eastell R, Reid IR, Boonen S, Cauley JA, Cosman F, Lakatos P, Leung PC, Man Z, Mautalen C, Mesenbrink P, Hu H, Caminis J, Tong K, Rosario-Jansen T, Krasnow J, Hue TF, Sellmeyer D, Eriksen EF, Cummings SR. Once-yearly zoledronic acid for treatment of postmenopausal osteoporosis. N Engl J Med. 2007;356(18):1809-22. [pmid: 17476007].
Black DM, Schwartz AV, Ensrud KE, Cauley JA, Levis S, Quandt SA, Satterfield S, Wallace RB, Bauer DC, Palermo L, Wehren LE, Lombardi A, Santora AC, Cummings SR. Effects of continuing or stopping alendronate after 5 years of treatment: the Fracture Intervention Trial Long-term Extension (FLEX): a randomized trial. JAMA. 2006;296(24):2927-38. [pmid: 17190893].
Cooper C. Beyond daily dosing: clinical experience. Bone. 2006;38(4 Suppl 1):S13-7.
Cranney A, Wells GA, Yetisir E, Adami S, Cooper C, Delmas PD, Miller PD, Papapoulos S, Reginster JY, Sambrook PN, Silverman S, Siris E, Adachi JD. Ibandronate for the prevention of nonvertebral fractures: a pooled analysis of individual patient data. Osteoporos Int. 2008. July. 29. ePub.
Delmas PD, Benhamou CL, Man Z, Tlustochowicz W, Matzkin E, Eusebio R, Zanchetta J, Olszynski WP, Recker RR, McClung MR. Monthly dosing of 75 mg risedronate on 2 consecutive days a month: efficacy and safety results. Osteoporos Int. 2008;19(7):1039-45. [pmid: 18087660].
Delmas PD, McClung MR, Zanchetta JR, Racewicz A, Roux C, Benhamou CL, Man Z, Eusebio RA, Beary JF, Burgio DE, Matzkin E, Boonen S. Efficacy and safety of risedronate 150 mg once a month in the treatment of postmenopausal osteoporosis. Bone. 2008;42(1):36-42. [pmid: 17920005].
Ensrud KE, Stock JL, Barrett-Connor E, Grady D, Mosca L, Khaw KT, Zhao Q, Agnusdei D, Cauley JA. Effects of raloxifene on fracture risk in postmenopausal women: the Raloxifene Use for the Heart Trial. J Bone Miner Res. 2008;23(1):112-20. [pmid: 17892376].
Greenspan SL, Bone HG, Ettinger MP, Hanley DA, Lindsay R, Zanchetta JR, Blosch CM, Mathisen AL, Morris SA, Marriott TB. Effect of recombinant human parathyroid hormone (1–84) on vertebral fracture and bone mineral density in postmenopausal women with osteoporosis: a randomized trial. Ann Intern Med. 2007;146(5):326-39. [pmid: 17339618].
Heckbert SR, Li G, Cummings SR, Smith NK, Psaty BM. Use of Alendronate and Risk of Incident Atrial Fibrillation in Women. Arch Intern Med. 2008;168(8):826-831. [pmid: 18443257].
Hochberg MC, Thompson DE, Black DM, Quandt SA, Cauley J, Geusens P, Ross PD, Baran D. Effect of alendronate on the age-specific incidence of symptomatic osteoporotic fractures. J Bone Miner Res. 2005;20(6):971-6. [pmid: 15883637].
Jackson RD, LaCroix AZ, Gass M, Wallace RB, Robbins J, Lewis CE, Bassford T, Beresford SA, Black HR, Blanchette P, Bonds DE, Brunner RL, Brzyski RG, Caan B, Cauley JA, Chlebowski RT, Cummings SR, Granek I, Hays J, Heiss G, Hendrix SL, Howard BV, Hsia J, Hubbell FA, Johnson KC, Judd H, Kotchen JM, Kuller LH, Langer RD, Lasser NL, Limacher MC, Ludlam S, Manson JE, Margolis KL, McGowan J, Ockene JK, O’Sullivan MJ, Phillips L, Prentice RL, Sarto GE, Stefanick ML, Van Horn L, Wactawski-Wende J, Whitlock E, Anderson GL, Assaf AR, Barad D. Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med. 2006;354(7):669-83. [pmid: 16481635].
Jamal SA, Bauer DC, Ensrud KE, Cauley JA, Hochberg M, Ishani A, Cummings SR. Alendronate treatment in women with normal to severely impaired renal function: an analysis of the fracture intervention trial. J Bone Miner Res. 2007;22(4):503-8. [pmid: 17243862].
Lock CA, Lecouturier J, Mason JM, Dickinson HO. Lifestyle interventions to prevent osteoporotic fractures: a systematic review. Osteoporos Int. 2006;17(1):20-8. [pmid: 15928799].
Lyles KW, Colon-Emeric CS, Magaziner JS, Adachi JD, Pieper CF, Mautalen C, Hyldstrup L, Recknor C, Nordsletten L, Moore KA, Lavecchia C, Zhang J, Mesenbrink P, Hodgson PK, Abrams K, Orloff JJ, Horowitz Z, Eriksen EF, Boonen S. Zoledronic acid and clinical fractures and mortality after hip fracture. N Engl J Med. 2007;357(18):1799-809. [pmid: 17878149].
Lyons RA, Johansen A, Brophy S, Newcombe RG, Phillips CJ, Lervy B, Evans R, Wareham K, Stone MD. Preventing fractures among older people living in institutional care: a pragmatic randomised double blind placebo controlled trial of vitamin D supplementation. Osteoporos Int. 2007;18(6):811-8. [pmid: 17473911].
Majumdar SR. (editorial/review) Oral Bisphosphonates and AF. BMJ. 2008;336(7648):784-785. [pmid: 18334526].
Mamdani M, Kopp A, Hawker G. Hip fractures in users of first- vs. second-generation bisphosphonates. Osteoporos Int. 2007;18(12):1595-600. [pmid: 17767369].
McCloskey EV, Beneton M, Charlesworth D, Kayan K, deTakats D, Dey A, Orgee J, Ashford R, Forster M, Cliffe J, Kersh L, Brazier J, Nichol J, Aropuu S, Jalava T, Kanis JA. Clodronate reduces the incidence of fractures in community-dwelling elderly women unselected for osteoporosis: results of a double-blind, placebo-controlled randomized study. J Bone Miner Res. 2007;22(1):135-41. [pmid: 17042717].
McClung M, Recker R, Miller P, Fiske D, Minkoff J, Kriegman A, Zhou W, Adera M, Davis J. Intravenous zoledronic acid 5 mg in the treatment of postmenopausal women with low bone density previously treated with alendronate. Bone. 2007;41(1):122-8. [pmid: 17468062].
Miller PD, Schwartz EN, Chen P, Misurski DA, Krege JH. Teriparatide in postmenopausal women with osteoporosis and mild or moderate renal impairment. Osteoporos Int. 2007;18(1):59-68. [pmid: 17013567].
Nguyen ND, Eisman JA, Nguyen TV. Anti-hip fracture efficacy of biophosphonates: a Bayesian analysis of clinical trials. J Bone Miner Res. 2006;21(2):340-9. [pmid: 16526127].
Palomba S, Orio F Jr, Manguso F, Falbo A, Russo T, Tolino A, Tauchmanova L, Colao A, Doldo P, Mastrantonio P, Zullo F. Efficacy of risedronate administration in osteoporotic postmenopausal women affected by inflammatory bowel disease. Osteoporos Int. 2005;16(9):1141-9. [pmid: 15928801].
Prince R, Sipos A, Hossain A, Syversen U, Ish-Shalom S, Marcinowska E, Halse J, Lindsay R, Dalsky GP, Mitlak BH. Sustained nonvertebral fragility fracture risk reduction after discontinuation of teriparatide treatment. J Bone Miner Res. 2005;20(9):1507-13. [pmid: 16059622].
Recker RR, Kendler D, Recknor CP, Rooney TW, Lewiecki EM, Utian WH, Cauley JA, Lorraine J, Qu Y, Kulkarni PM, Gaich CL, Wong M, Plouffe L Jr, Stock JL. Comparative effects of raloxifene and alendronate on fracture outcomes in postmenopausal women with low bone mass. Bone. 2007;40(4):843-51. [pmid: 17182297].
Roux C, Reginster JY, Fechtenbaum J, Kolta S, Sawicki A, Tulassay Z, Luisetto G, Padrino JM, Doyle D, Prince R, Fardellone P, Sorensen OH, Meunier PJ. Vertebral fracture risk reduction with strontium ranelate in women with postmenopausal osteoporosis is independent of baseline risk factors. J Bone Miner Res. 2006;21(4):536-42. [pmid: 16598373].
Saag KG, Shane E, Boonen S, Marin F, Donley DW, Taylor KA, Dalsky GP, Marcus R. Teriparatide or alendronate in glucocorticoid-induced osteoporosis. N Engl J Med. 2007;357(20):2028-39. [pmid: 18003959].
Seeman E, Crans GG, Diez-Perez A, Pinette KV, Delmas PD. Anti-vertebral fracture efficacy of raloxifene: a meta-analysis. Osteoporos Int. 2006;17(2):313-6. [pmid: 16217588].
Seeman E, Devogelaer JP, Lorenc R, Spector T, Brixen K, Balogh A, Stucki G, Reginster JY. Strontium ranelate reduces the risk of vertebral fractures in patients with osteopenia. J Bone Miner Res. 2008;23(3):433-8. [pmid: 17997711].
Silverman SL, Christiansen C, Genant HK, Vukicevic S, Zanchetta JR, de Villiers TJ, Constantine GD, Chines AA. Efficacy of Bazedoxifene in Reducing New Vertebral Fracture Risk in Postmenopausal Women With Osteoporosis: Results From a 3-Year, Randomized, Placebo-and Active-Controlled Clinical Trial*. J Bone Miner Res. Dec. 2008;23(12):1923-34. [pmid: 18665787].
Silverman SL, Watts NB, Delmas PD, Lange JL, Lindsay R. Effectiveness of bisphosphonates on nonvertebral and hip fractures in the first year of therapy: the risedronate and alendronate (REAL) cohort study. Osteoporos Int. 2007;18(1):25-34. [pmid: 17106785].
Siris ES, Harris ST, Eastell R, Zanchetta JR, Goemaere S, Diez-Perez A, Stock JL, Song J, Qu Y, Kulkarni PM, Siddhanti SR, Wong M, Cummings SR. Skeletal effects of raloxifene after 8 years: results from the continuing outcomes relevant to Evista (CORE) study. J Bone Miner Res. 2005;20(9):1514-24. [pmid: 16059623].
Siris ES, Simon JA, Barton IP, McClung MR, Grauer A. Effects of risedronate on fracture risk in postmenopausal women with osteopenia. Osteoporos Int. 2008;19(5):681-6. [pmid: 17968610].
Sørensen HT, Christensen S, Mehnert F, Pedersen L, Chapurlat RD, Cummings SR, Baron JA. Use of bisphosphonates among women and risk of atrial fibrillation and flutter: population based case-control study. BMJ. April. 12. 2008;336(7648):813-816. [pmid: 18334527].
Tang BM, Eslick GD, Nowson C, Smith C, Bensoussan A. Use of calcium or calcium in combination with vitamin D supplementation to prevent fractures and bone loss in people aged 50 years and older: a meta-analysis. Lancet. 2007;370(9588):657-66. [pmid: 17720017].
Vestergaard P, Jorgensen NR, Mosekilde L, Schwarz P. Effects of parathyroid hormone alone or in combination with antiresorptive therapy on bone mineral density and fracture risk--a meta-analysis. Osteoporos Int. 2007;18(1):45-57. [pmid: 16951908].
Watts NB, Chines A, Olszynski WP, McKeever CD, McClung MR, Zhou X, Grauer A. Fracture risk remains reduced one year after discontinuation of risedronate. Osteoporos Int. 2008;19(3):365-72. [pmid: 17938986].
Watts NB, Geusens P, Barton IP, Felsenberg D. Relationship between changes in BMD and nonvertebral fracture incidence associated with risedronate: reduction in risk of nonvertebral fracture is not related to change in BMD. J Bone Miner Res. 2005;20(12):2097-104. [pmid: 16294263].

## CER 13. Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer

For this assessment, a limited literature search was conducted for the years 2006–2008. This search included the five generalist journals listed in the Methods; and three specialty journals (as recommended by the subject matter experts): Journal of Urology, Journal of Clinical Oncology, and Cancer. The search identified 540 titles, of which 16 were obtained in full text for further review. The remaining titles were rejected because they were editorials, letters, or non-systematic reviews, or did not include topics of relevance. Of the 16 selected for further review, 11 were abstracted. The remaining articles were rejected because they had already been included in the earlier report or did not include a comparison of interest. An additional 7 articles suggested by the experts were also reviewed and included.

We consulted the project lead as well as three members of the TEP and two additional subject matter experts. Of these six individuals, five responded.

Table 2.11 shows the original key questions, the conclusions of the original report, the results of the literature and drug database searches, the experts’ assessments, and the recommendations of the SCEPC regarding the need for update.

Table 2.11 CER 13. Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer: Are the conclusions still valid?

Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | Expert Opinions | Conclusion from SC EPC
Conclusions From CER Executive Summary | Summary of SC EPC Literature Search | FDA/Health Canada Info | EPC Investigator 2 TEP Members 1 Other Expert | Conclusion from SC EPC
Key Question 1: What are the comparative risks, benefits, short-and long-term outcomes of the following therapies for clinically localized prostate cancer (e.g., Radical prostatectomy, including perineal and retropubic approaches, and open vs. laparoscopic vs. no lymphadenectomy, External beam radiotherapy, including standard therapy, and therapies designed to decrease exposure to normal tissues such as 3D conformal radiation therapy and Intensity Modulated Radiation Therapy, Interstitial brachytherapy, Cryosurgery, Expectant management (“watchful waiting”), and Hormonal therapy as primary therapy, adjuvant or neoadjuvant to other therapies)?
No one therapy can be considered the preferred treatment for localized prostate cancer patient must make trade offs between estimated treatment effectiveness, necessity, and adverse effects. All treatment options result in adverse effects (primarily urinary, bowel, and sexual), although the severity and frequency may vary between treatments. Even if differences in therapeutic effectiveness exist, differences in adverse effects, convenience, and costs are likely to be important factors in individual patient decision making. Patient satisfaction with therapy is high and associated with several clinically relevant outcome measures. | An observational cohort using Surveillance, Epidemiology and End Result (SEER) data from 44,630 patients (32, 022 receiving treatment, 12,607 in the observation group) found, at 12 years of follow up, that active treatment was associated with significantly better survival (adjusted hazard ratio [HR] of 0.69, 95% CI 0.66–0.72). Adjusted HR for specific treatment: radical prostatectomy 0.50 (91% CI 0.47–0.53); radiation 0.81 (95% CI 0.78–0.85) (Wong, 2006). In the Scandinavian Prostate Cancer Group Study #4, 695 men with clinically localized prostate cancer were randomized to prostatectomy or watchful waiting (WW). At 12 years of follow up, the relative risk of death was decreased in the prostatectomy group: 0.65 (95% CI 0.45, 0.93); and there was a similar reduction in distant metastases (Bill-Axelson, 2008). | Not applicable. | Four experts agreed that a 12-year update of a previously included randomized trial of surgery versus watchful waiting (WW) is consistent with the original findings although it offers longer follow-up. While useful to describe, it is unlikely to dramatically alter findings (Bill-Axelson, 2008). | Conclusion is possibly out of date and this portion of the CER may need updating due to longer term follow up data.
Compared with men who used WW, men with clinically localized prostate cancer detected by methods other than prostate specific antigen (PSA) testing and treated with radical prostatectomy (RP) experienced fewer deaths from prostate cancer, marginally fewer deaths from any cause, and fewer distant metastases. | At 12 years follow-up, in the Scandinavian Prostate Cancer Group Study #4, the relative risk of death was decreased in the prostatectomy group: 0.65 (95% CI 0.45, 0.93); and there was a similar reduction in distant metastases (Bill-Axelson, 2008). | Not applicable. | One expert noted that the P value for overall survival is no longer statistically significant, although there are trends towards a benefit. No benefit was seen in men aged > 65 for overall, disease-specific survival or metastases. Another expert referred to Bill-Axelson, 2008. | Conclusion is probably out of date and this portion of the CER may need updating based on longer follow up data in the original study and expert opinion.
Radical prostatectomy vs. external beam radiotherapy (EBRT). One small older trial indicated that, compared with EBRT, RP was more effective in preventing progression, recurrence, or distant metastases in men with clinically localized prostate cancer detected by methods other then PSA testing. | An observational cohort (1,618 patients who received surgery, 702 who received external beam radiation, and 114 in the observation group) that found that, at 13 years of follow up, prostate cancer mortality among patients with clinically localized cancer was 2.2–3.8 times higher in patients receiving EBRT than in patients receiving surgery (Albertsen, 2007). | Not applicable. | One expert called attention to Albertsen, 2007, an observational population-based cohort “study, which showed a survival benefit to surgery over EBRT in certain risk groups. However, these are level II data.” | Conclusion is possibly out of date and this portion of the CER may need updating based on new data that may change the conclusion.
The addition of neoadjuvant hormonal therapy to RP did not improve survival or cancer recurrence rates, defined by PSA recurrence, but increased AEs. | No new evidence. | Not applicable. | No expert response. | Conclusion is still valid and this portion of the CER does not need updating.
It is not known if using higher doses of EBRT by increasing either the total amount or type of radiation (e.g., via high-dose intensity modulated or proton beam or by adding brachytherapy) improves overall or disease-specific survival compared with other therapies. No EBRT regimen, whether conventional, high-dose conformal, dose fractionation, or hypofractionation, was superior in reducing overall or disease-specific mortality. | No new evidence. | Not applicable. | One expert agreed there was no new evidence. Two experts responded that they do not know. One cited two RCTs (Pollack, 2002 and Zietman, 2005), that demonstrated that higher dose radiation may decrease risk of PSA recurrence, which may change this conclusion. [Note: Both of these studies were included in the original CER] The other responded, “There are certainly no new level I trials showing that higher doses of EBRT are more effective than lower doses but the weight of observational cohorts and what appears to be better survival curves with more contemporary cohorts seem to favor higher doses being more effective, although the data are by no means conclusive in my opinion. However, I am reluctant to endorse the conclusion because, while the wording states ‘it is not known,’ this could be interpreted as ‘it is unlikely that.’ ” | Conclusion is probably out of date and this portion of the CER may need updating based on new evidence and expert opinion.
Androgen deprivation therapy (ADT) combined with external beam radiotherapy (EBRT) (ADT + EBRT) may decrease overall and disease-specific mortality but increase adverse events (AEs) compared with EBRT alone in high-risk patients defined by PSA levels and Gleason histologic score. One RCT found that conformal EBRT combined with 6 months of ADT reduced all-cause mortality, disease-specific mortality, and PSA failure compared with conformal EBRT alone after a median followup of 4.5 years. There were significant increases in gynecomastia and impotence in the ADT + EBRT group compared with EBRT alone. | A RCT of 206 patients found, at a median of 7.6 years of follow up, that men receiving radiation therapy alone had a significant increase in overall mortality (HR = 1.8, 95% CI 1.1, 2.09) compared to men receiving radiation therapy plus androgen deprivation therapy. The effect was most pronounced in men with no or minimal comorbidities (D’Amico., 2008). | Not applicable. | Two experts agreed that the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
One small trial comparing different doses of supplemental EBRT, 20 Gy vs. 44 Gy, adjuvant to brachytherapy (103Pd) implant found no significant differences in the number of biochemical failure events and freedom from biochemical progression at 3 years. Preliminary results from one small trial comparing ^125^I with ^103^Pd brachytherapy found similar biochemical control at 3 years. There was a trend toward more radiation proctitis, defined as persistent bleeding, with ^125^I. | No new evidence. | Not applicable. | Three experts agreed that the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
ADT with bicalutamide alone or in addition to RP or EBRT did not reduce cancer recurrence or mortality. | No new evidence. | Not applicable. | Three experts agreed that the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
When adjusting for baseline factors, erectile dysfunction (ED) was greater with RP compared to EBRT. | A prospective cohort study assessed 1201 patients at baseline and after receipt of radical prostatectomy, brachytherapy, or external beam radiation therapy. Distinct patterns-of-life changes were associated with each treatment; each affected sexuality, but patients receiving prostatectomy had greater decreases in sexuality and in spousal distress. Nerve-sparing operations were associated with better recovery of sexual function than procedures that were not nerve sparing (Sanda, 2008). | Not applicable. | One expert responded that it is likely there are additional population-based studies though these studies are unlikely to change the findings. One expert responded that recovery of sexual function depends on whether surgery was nerve-sparing or non-nerve-sparing (Sanda, 2008). One expert noted that he did not know, and added: “This is true up to 5 years after diagnosis, but it is difficult to say whether or not this is true beyond this. You need to put a time reference on this conclusion.” | Conclusion is possibly out of date and this portion of the CER may need updating based on a diversity of expert opinion.
No randomized trials evaluated cryosurgery and the majority of reports included patients with T3–T4 stages. Overall or prostate-cancer-specific survival was not reported. Progression-free survival in patients with T1–T2 stages ranged from 29 to 100 percent. AEs were often not reported but, when described, included bladder outlet obstruction (3 to 21 percent), tissue sloughing (4 to 15 percent), and impotence (40 to 100 percent). Outcomes may be biased by patient and provider characteristics. | Bill-Axelson study was summarized above (Bill-Axelson, 2008). | Not applicable. | One expert advised referring to Bill-Axelson, 2008 for updated analysis of the Scandinavian trial. | Conclusion is possibly out of date and this portion of the CER may need updating based on longer follow-up data from a seminal RCT.
Three reviews estimated the effectiveness and AEs of laparoscopic and robotic assisted prostatectomy. Median followup was 8 months. Laparoscopic RP had longer operative time but lower blood loss and improved wound healing compared with open retropubic RP. Results from eight nonrandomized reports suggested that total complications, continence rates, positive surgical margins, and operative time were similar for robotic assisted and open RP. Median length of hospital stay and median length of catheterization were shorter after robotic assisted RP than open RP. | An analysis of Medicare claims data (n=2702) of men undergoing minimally invasive prostatectomy or open prostatectomy found fewer perioperative complications in patients undergoing minimally invasive procedures (30% vs. 36 %) but higher rates of salvage therapy (28% vs. 9%) (Hu, 2008). | Not applicable. | One expert responded that new information is likely available from case series. Two experts cited a study that demonstrated higher risk of secondary therapies for patients undergoing minimally invasive RP (Medicare analysis) (Hu, 2008). One of these experts also cited reports from Europe indicating that, at least in pT3 patients, margin positive rates are higher in the laparoscopic group. [Note: We did not find this study in our limited literature search] | Conclusion is probably out of date and this portion of the CER may need updating based on new evidence and expert opinion.
There was no direct evidence that Intensity Modulated Radiation Therapy (IMRT) results in better survival or disease-free survival than other therapies for localized prostate cancer. Based on nonrandomized data, the absolute risks of clinical and biochemical outcomes (including tumor recurrence), toxicity, and quality of life after IMRT are comparable with conformal radiation. There is low-level evidence that IMRT provides at least as good a radiation dose to the prostate with less radiation to the surrounding tissues compared with conformal radiation therapy | No new evidence. | Not applicable. | One expert noted that there have been no RCTs. A meeting will be held with AHRQ this summer to consider planning a prospective cohort study to evaluate IMRT. | Conclusion is still valid and this portion of the CER does not need updating.
There were no data from randomized trials comparing HIFU (High Intensity Focused Ultrasound) with other primary treatment options. Biochemical progression-free survival rates of 66 to 87 percent and negative biopsy rates of 66 to 93 percent were reported from noncontrolled studies. The absolute risk of impotence and treatment-related morbidity appeared to be similar to other treatments. Followup duration was <10 years. | No new evidence. | Not applicable. | Two experts noted that the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Bother due to dripping or leaking of urine was more than six-fold greater in RP-treated men than in men treated with EBRT after adjusting for baseline factors. In a subgroup of men ages 70 and over, bother due to urine, bowel, or sexual dysfunction was 5.1, 2.4, and 2.8 times higher, respectively, for aggressive (RP/EBRT) vs. conservative (WW/ADT) therapy. Satisfaction with treatment was high, with less than 5 percent reporting dissatisfaction, unhappiness, or feeling terrible about their treatment, although the highest percent was among those treated with RP. | A prospective cohort study assessed quality-of-life domains in 1,201 patients and 625 spouses and reported distinct quality-of-life changes for different prostate cancer treatments (Sanda, 2008). | Not applicable. | One expert said that it is likely there are new case series and population-based cohort studies that might refine the estimates, although it has been only 1 year or so since the original CER was completed. One expert said that the difference between EBRT and RP in terms of dripping or leaking urine may not be as great as expressed here, especially with longer-term follow-up, and cited as examples Sanda, 2008 and Miller DC, et al, J Clin Oncol, 2005 (Miller, 2005). | Conclusion is possibly out of date and this portion of the CER may need updating based on expert opinion.
Key Question 2: How do specific patient characteristics, e.g., age, race/ethnicity, presence or absence of comorbid illness, preferences (e.g., tradeoff of treatment-related adverse effects vs. potential for disease progression) affect the outcomes of these therapies, overall and differentially?
No RCTs reported head-to-head comparisons of treatment outcomes stratified by race/ethnicity, and most did not provide baseline racial characteristics. Available data were largely from case series. Few studies reported head-to-head comparisons, and there was limited adjustment for confounding factors. Modest treatment differences reported in some nonrandomized studies have not been consistently reported in well-powered studies. There was little evidence of a differential effect of treatments based on age. While differences exist in the incidence and morbidity of prostate cancer based on patient age and there are differences in the treatments offered to men at different age ranges, few studies directly compared the treatment effects of different therapies across age groups. Most RCTs did not have age exclusion criteria. The mean/median age ranged from a low of 63 years for trials of RP to 72 years for trials of EBRT. Only one RCT provided subgroup analysis according to age. Results suggest that survival benefits of RP compared with WW may be limited to men under 65 years of age. Practice patterns from observational studies show that RP is the most common treatment option in younger men with localized prostate cancer. | No new evidence. | Not applicable. | One expert stated that there was no new evidence. An RCT in the U.S. comparing surgery to watchful waiting in patients in whom prostate cancer was detected primarily by PSA and enrolling approximately 30% African-Americans is scheduled for completion in early 2010. One expert cited Bill-Axelson, 2005 (included in original report) and Bill-Axelson, 2008. As described above, the latter reports data from Scandinavian RCT that suggests strongly that benefits of local therapy are concentrated among men <65 years. One expert agreed that the conclusion is still valid. | Conclusion is possibly out of date and this portion of the CER may need updating based on difference in expert opinion.
Key Question 3: How do provider/hospital characteristics affect outcomes overall and differentially (e.g., geographic region and volume)?
Results from national administrative databases and surveys suggested that provider/hospital characteristics, including RP procedure volume, physician specialty, and geographic region, affect outcomes. Clinicians were more likely to recommend procedures they performed regardless of tumor grades and PSA levels. | No new evidence. | Not applicable. | One expert said that there is at least 1 study assessing volume and outcomes for radiation therapy and 1–2 additional studies for surgery. (Note: See below) | Conclusion is still valid and this portion of the CER does not need updating.
Surgeon RP volume was not associated with RP-related mortality and positive surgical margins. However, the relative risk of surgery-related complications adjusted for patient age, race, and comorbidity and for hospital type and location was lower in patients treated by higher volume surgeons. Urinary complications and incontinence were lower for patients whose surgeons performed more than 40 RPs per year. The length of hospital stay was shorter in patients operated on by surgeons who performed more RPs per year. | A cohort study of 7,765 prostate cancer patients treated with radical prostatectomy from 72 surgeons at major academic medical centers found a steep learning curve that did not plateau until approximately 250 operations had been performed. (Vickers, 2007). | Not applicable. | One expert noted that there is at least 1 study assessing volume and outcomes for radiation therapy and 1–2 additional studies for surgery. One expert said that recent data suggest that surgeon volume is also associated (inversely) with prostate cancer PSA and recurrence after radical prostatectomy (Vickers, 2007). One expert said he was not sure he agrees with this conclusion. “Specifically, I believe that there are now data from the Memorial group that volume correlates with margin status. However, everything else is true.” | Conclusion is probably out of date and this portion of the CER may need updating based on difference in expert opinion.
Surgery-related mortality and late urinary complications were lower and length of stay was shorter in hospitals that performed more RPs per year. Hospital readmission rates were lower in hospitals with greater volume. Teaching hospitals had a lower rate of surgery-related complications and higher scores of operative quality. Several studies found differences in treatment and outcome based on whether the patient was seen in an HMO (health maintenance organization) or fee-for-service organization and whether the patient was a Medicare beneficiary. Variability in the use of ADT was more attributable to individual differences among urologists than tumor or patient characteristics. | An analysis of SEER data for 82, 735 men with prostate cancer found use of ADT by urologists varied by characteristics of the urologist (Shahinian 2007). | Not applicable. | One expert noted that there is at least 1 study assessing volume and outcomes for radiation therapy and 1–2 additional studies for surgery. One expert also cited Shahinian, 2007 for additional details regarding ADT use among urologists. | Conclusion is possibly out of date and this portion of the CER may need updating based on expert opinion.
Key Question 4: How do tumor characteristics, e.g., Gleason score, tumor volume, screen vs. clinically detected tumors, and PSA levels, affect the outcomes of these therapies, overall and differentially?
Little data exists on the comparative effectiveness of treatments based on PSA levels, histologic score, and tumor volume to identify low-, intermediate-, and high-risk tumors. We focused on baseline PSA levels and Gleason histologic score. The natural history of PSA-detected tumors is not known because few men remain untreated for a long period. One report assessed 20-year outcomes in the U.S. from men with prostate cancer detected prior to PSA testing and treated with WW. Histologic grade was associated with overall and prostate-cancer-specific survival. Men with low-grade prostate cancers had a minimal risk of dying from prostate cancer. Men with high-grade prostate cancers had a high probability of dying from their disease within 10 years of diagnosis, regardless of their age at diagnosis. Estimates from large ongoing screening trials suggest that PSA increases the time of detection by 5–15 years. Therefore, it is likely that men with PSA-detected tumors will have better 20-year disease-specific survival than this cohort. | No new evidence. | Not applicable. | Two experts agreed that the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Based on very limited nonrandomized trial data, disease-specific survival was similar for men treated with EBRT or with RP in men with baseline PSA >10 ng/ml. Men with Gleason scores 8–10 were more likely to have biochemical recurrence than men with Gleason scores 2–6, regardless of type of treatment. | No new evidence. | Not applicable. | Two experts agree that the conclusion is still valid. | Conclusion is still valid and this portion of the CER does not need updating.
Are there new data that could inform the key questions that might not be addressed in the conclusions? Results of the longstanding PIVOT Trial should be available relatively soon, which will be the largest and most informative trial fo screening in the US and can be expected to influence the “expected management/watchful waiting” aspect of the CER. (Wilt, 2009)

Legend: ADT: androgen deprivation therapy; EBRT: external beam radiotherapy; ED: erectile dysfunction; IMRT: intensity modulated radiation therapy; PIVOT Trial: Prostate cancer Intervention Versus Observation Trial; PSA: prostate specific antigen; RCT: randomized controlled trial; RP: radical prostatectomy; WW: watchful waiting

### References

Albertsen PC, Hanley JA, Penson DF, Barrows G, Fine J. 13-year outcomes following treatment for clinically localized prostate cancer in a population based cohort. J Urol. Mar. 2007;177(3):932-936. [pmid: 17296379].
Bill-Axelson A, Holmberg L, Filen F, et al. Radical prostatectomy versus watchful waiting in localized prostate cancer: the Scandinavian prostate cancer group-4 randomized trial. J Natl Cancer Inst. Aug 20. 2008;100(16):1144-1154. [pmid: 18695132].
Bill-Axelson A, Holmberg L, Ruutu M, et al. Radical prostatectomy versus watchful waiting in early prostate cancer. N Engl J Med. May 12. 2005;352(19):1977-1984. [pmid: 15888698].
D’Amico AV, Chen MH, Renshaw AA, Loffredo M, Kantoff PW. Androgen suppression and radiation vs radiation alone for prostate cancer: a randomized trial. JAMA. Jan 23. 2008;299(3):289-295. [pmid: 18212313].
Hon NH, Brathwaite D, Hussain Z, et al. A prospective, randomized trial comparing conventional transurethral prostate resection with PlasmaKinetic vaporization of the prostate: physiological changes, early complications and long-term followup. J Urol. Jul. 2006;176(1):205-209. [pmid: 16753403].
Hu JC, Wang Q, Pashos CL, Lipsitz SR, Keating NL. Utilization and outcomes of minimally invasive radical prostatectomy. J Clin Oncol. May 10. 2008;26(14):2278-2284. [pmid: 18467718].
Liu L, Coker AL, Du XL, Cormier JN, Ford CE, Fang S. Long-term survival after radical prostatectomy compared to other treatments in older men with local/regional prostate cancer. J Surg Oncol. Jun 1. 2008;97(7):583-591. [pmid: 18381603].
Miller DC, Sanda MG, Dunn RL, et al. Long-term outcomes among localized prostate cancer survivors: health-related quality-of-life changes after radical prostatectomy, external radiation, and brachytherapy. J Clin Oncol. Apr 20. 2005;23(12):2772-2780. [pmid: 15837992].
Pollack A, Zagars GK, Starkschall G, et al. Prostate cancer radiation dose response: results of the M. D. Anderson phase III randomized trial. Int J Radiat Oncol Biol Phys. Aug 1. 2002;53(5):1097-1105. [pmid: 12128107].
Sanda MG, Dunn RL, Michalski J, et al. Quality of life and satisfaction with outcome among prostate-cancer survivors. N Engl J Med. Mar 20. 2008;358(12):1250-1261. [pmid: 18354103].
Sandler HM. Exploring dose-intensity: carefully comparing high-dose with low-dose external-beam radiotherapy for prostate cancer. J Clin Oncol. May 1. 2006;24(13):1975-1977. [pmid: 16648496].
Shahinian VB, Kuo YF, Freeman JL, Orihuela E, Goodwin JS. Characteristics of urologists predict the use of androgen deprivation therapy for prostate cancer. J Clin Oncol. Dec 1. 2007;25(34):5359-5365. [pmid: 18048816].
Vickers A, Lilja H, Scardino P. Five genetic variants associated with prostate cancer. N Engl J Med. Jun. 19. 2008;358(25):2740. author reply 2741.
Vickers AJ, Bianco FJ, Serio AM, et al. The surgical learning curve for prostate cancer control after radical prostatectomy. J Natl Cancer Inst. Aug 1. 2007;99(15):1171-1177. [pmid: 17652279].
Wilt TJ. Commentary: controversies in NICE guidance on prostate cancer. BMJ. Mar 15. 2008;336(7644):612-614. [pmid: 18340077].
Wilt TJ, Brawer MK, Barry MJ, Jones KM, Kwon Y, Gingrich JR, Aronson WJ, Nsouli I, Iyer P, Cartagena R, Snider G, Roehrborn C, Fox S. The Prostate cancer Intervention Versus Observation Trial:VA/NCI/AHRQ Cooperative Studies Program #407 (PIVOT): design and baseline results of a randomized controlled trial comparing radical prostatectomy to watchful waiting for men with clinically localized prostate cancer. Contemp Clin Trials. Jan. 2009;30(1):81-7. [pmid: 18783735].
Wong YN, Mitra N, Hudes G, et al. Survival associated with treatment vs observation of localized prostate cancer in elderly men. JAMA. Dec 13. 2006;296(22):2683-2693. [pmid: 17164454].
Yu JS, Roach M 3rd. Quality of life and satisfaction with outcome among prostate-cancer survivors. N Engl J Med. Jul. 10. 2008;359(2):200. author reply 201–202.
Zietman AL, DeSilvio ML, Slater JD, et al. Comparison of conventional-dose vs high-dose conformal radiation therapy in clinically localized adenocarcinoma of the prostate: a randomized controlled trial. JAMA. Sep 14. 2005;294(10):1233-1239. [pmid: 16160131].