# Results

## Registry Search Yield

As can be seen in Figure 1, the searches of ClinicalTrials.gov and ICTRP returned 665 records, of which 29 studies in 30 records were determined to be relevant for the project. Of these, four matched papers cited in the original review, none with results. Twenty-three did not have matching papers in the original review, and two of these had results reported in the trial registry. The greatest amount of that time was in the screening of the 665 records retrieved and in the matching and evaluation of the relevant records. The time screening could have been reduced by (1) searching only ClinicalTrials.gov, but relevant records from ICTRP would have been missed; or (2) searching ClinicalTrials.gov, using the advanced search function with the otorrhea terms in the population field and tympanostomy terms in the intervention field. This strategy returned only 77 records, and that set included all of the records eventually screened in as relevant. This was a project where the limitations of the ICTRP search interface were apparent, requiring that we use a very general search for only the intervention terms and screen over 500 records to find the 10 eventually included in the analysis.

Figure 1 Literature flow

RCT: randomized controlled trial; CT.gov: ClinicalTrials.gov; ICTRP: International Clinical Trials Registry Platform; NRCS: non-randomized comparative study; KQ: key question.

Figure 1 shows the literature flow for studies and records in the review. Overall, the searches identified 665 unique records, of which 28 were deemed relevant. The original report included 178 studies of which 6 were matched to records, 1 with results. 22 studies were not matched to the original report, 2 with results.

## Comparison of Registry Searches with Original Review

The original review included 178 studies, 11 (studies) of which were identified in the registry record search. Table 1 gives basic information on all 28 relevant records from the registry searches, with the six that were also in the original review at the top.

Table 1 Overall description of studies found

Study Identifier | Papers Author, year, PMID | Registry | Prospective/retrospective | Dates | Target N | Key Question
In report
NCT00365092 | Paradise 2001 11309632 | CT.gov | Retrospective | 2002–2006 | 400 | 1
ISRCTN35793977 | MRC Multicentre Otitis Media Study Group 2012 (TARGET) 22443163 | ICTRP/ISRCTN | Retrospective | 1994–1997 | 590 | 1
ISRCTN57358603 | Maw, 1999, 10459904 | ICTRP/ISRCTN | Retrospective | 1994–1997 | NR | 1
NCT00629694 | Vlastos 2011 21205368 5/2007-5/2008 Greece | Ct.gov | Retrospective | 2007–2009 | 52 | 1
NCT00162994 | Kujala, 2014, 24445832; Kujala, 2012, 22466327 | CT.gov | Retrospective | 2002–2005 | 300 | 2
NCT01949142 and NCT01949155 | Mair, 2016, 26985629 | Ct.gov (identified through ICTRP) | Prospective | 2013–2014 | 530 | 5
Not in report, with results
NCT01404611 | | CT.gov | Prospective | 2011–2013 | 331 | 5
NCT01908803 | | CT.gov | Prospective | 2013–2014 | 84 | 5
Not in report, no results
NCT02546518 | | CT.gov | Prospective | 2015–2016 | 80 | 1
NCT00016497 | | CT.gov | Retrospective | 1997–2007 | No data | 1
NCT01071902 | | CT.gov | Prospective | 2010–2011 | 400 | 1
NCT02490332 | | CT.gov | Prospective | 2015–2020 | 400 | 1
ACTRN12613000102774 | | ICTRP/ANZCTR | Prospective | 2014- | 280 | 1
NCT00809601 | | CT.gov | Prospective | 2008–2015 | 400 | 1,2
ACTRN12611001073998 | | ICTRP/ANZCTR | Prospective | 2014- | 200 | 1,2
NCT02038400 | | CT.gov | Prospective | 2013- | 140 | 2
NCT02567825 | | CT.gov | Prospective | 2015–2021 | 240 | 2
ACTRN12611000380998 | | ICTRP/ANZCTR | Prospective | 2011- | 200 | 2,3
NCT01111877 | | CT.gov | Prospective | 2010–2011 | 1389 | 3
NCT01437436 | | CT.gov | Retrospective | 2010–2012 | 120 | 3
NCT02165384 | | CT.gov | Retrospective | 2014–2016 | 250 | 3
NCT00578474 | | CT.gov | Retrospective | 2005–2008 | 911 | 5
NCT00578773 | | CT.gov | Retrospective | 2007–2009 | 303 | 5
NCT00579189 | | CT.gov | Retrospective | 2006–2009 | 776 | 5
NCT01994642 | | CT.gov | Prospective | 2013–2016 | 203 | 5
IRCT2013112315496N1 | | ICTRP/IRCT | Retrospective | 2006- | 530 | 5
EUCTR2009-017319-13-BE | | ICTRP/EUCTR | Prospective | 2011- | 1300 | 5
EUCTR2010-023239-40-ES | | ICTRP/EUCTR | Retrospective | 2011- | 330 | 5

CT.gov: ClinicalTrials.gov, ICTRP: International Clinical Trials Registry; ANZCTR: Australian New Zealand Clinical Trials Registry; IRCT: Iranian Registry of Clinical Trials; ISRCTN: International Standard Registered Clinical/soCial sTudy Number; EUCTR: European Union Clinical Trails Registry; PMID: PubMed Identifier.

### Studies Included in the Original Review, With a Registry Record

Only six studies (in seven records) matched papers in the original review. All were identified based on the papers attached to the registry record. Matching based on trial title, author, study title, and population information helped us identify one study that did not have an NCT number in the MEDLINE record or publication listed in the registry record (NCT00629694). Only one record gave baseline data and results, but we were able to compare design, interventions, and outcomes across the all six studies, which were published in eleven papers. We also performed risk of bias analysis based on the limited information included in the records, comparing that to the risk of bias information from the papers.

#### Study Design

Table 2 includes the basic design characteristics that were extracted for the original review. Other than level of detail given and occasional differences in the age ranges, the study descriptions were very close between the records and the resulting papers. There is little indication of reporting bias in the papers, and in fact the only instance in which funding source did not agree was in Paradise, where the record indicated only government funding and the paper referred to both government and industry funding.

Table 2 Design characteristics

Study | Study design | Funding source | Inclusion criteria | Age range (y) | Number of assessments/followup duration (weeks)
NCT00365092 | RCT | Government | Persistent middle-ear effusion, otherwise healthy. | <0.17 at enrollment (<4 at randomization) | nr/572
Paradise 2001 11309632 ^18–22^ | RCT | Government/Industry | Middle ear effusion that appeared substantial in quantity and persisted despite treatment with anti-microbial drugs for 90 days in the case of bilateral effusion or 135 days in the case of unilateral effusion.audiometric examinations; | 0.04–1.17 | nr/572
ISRCTN35793977 | RCT | Government | No previous ear or adenoid surgery, having B+B or B+C2 tympanograms and a bilateral average hearing threshold greater than 20 dB, plus an air-bone gap greater than 10 dB HL. Excluded: Children with severe general disease, craniofacial abnormalities, sensorineural losses, parents with language or literacy problems. A few children are also excluded if a consultant feels it would be unethical to randomise them into the study. | 3.5–7 | NR
MRC Multicentre Otitis Media Study Group 2012 (TARGET) 22443163^23^ | RCT | Government | Bilateral OME over 12-week watchful waiting period; excluded History of ear or adenoid surgery | 3.25–6.75 | 5/104
ISRCTN57358603 | RCT | Government | Confirmed bilateral otitis media with effusion (OME). Bilateral hearing impairment of 25–70 dB of at least 3 months’ duration | DOB 4/1/1991-DOB 12/31/1992 | NR
Maw 1999 10459904^24^ | RCT | Government | Confirmation of bilateral OME by otoscopy; disruptions to speech, language, learning, or behaviour | DOB 4/1/1991-DOB 12/31/1992 | 2/78
NCT00629694 | RCT | Academic Hospital | [underlined: Inclusion Criteria:] children operated for their adenoid hyperthrophy with an adenoid size of 3 (measured in a scale of 1–3 intraoperatively or from lateral neck x-ray) and otitis media with effusion causing an average air-bone gap of greater than 20db. Children should be otherwise healthy with an ASA score of I and between 3–12 years old of age [underlined: Exclusion Criteria:] other health problems especially related with the condition eg cleft palate | 3–12 | NR/52
Vlastos 2011 21205368 5/2007-5/2008 Greece^25^ | RCT | Not reported | The diagnosis of OME was based on otoscopy, tympanography and pure tone audiometry. Specifically, the presence of an opaque or thickened tympanic membrane, air–fluid level, or bubbles, or the inability to visualize the incudostapedial joint, were considered signs of OME, in children with a type B tympanogram (compliance <0.2 ml) and an audiogram with an air–bone gap of 20 dB or a hearing loss of 30 dB but no more than 55 dB in at least one frequency in both ears. Absence of the light reflex was not regarded as a specific sign of OME.; Absence of the light reflex was not regarded as a specific sign of OME; Absence of the light reflex was not regarded as a specific sign of OME | 3–7 | 3/52
NCT00162994 | RCT | Academic/Hospital | [underlined: Inclusion Criteria]: at least 3 otitis media episodes during the last half year; address near (< 50 km) the university hospital of Oulu [underlined: Exclusion Criteria:] otitis media effusion lasting longer than two months without acute exacerbations; prior adenoidectomy or tympanostomy; head or neck malformation; retarded child serious disease; chemoprophylaxis for another disease | 0.83–2
Kujala 2012 22466327, 24445832 3/2002–6/2004 Finland^26, 27^ | RCT | Academic/Hospital | [underlined: Inclusion Criteria:] at least 3 AOM episodes during the past 6 months; [underlined: Exclusion criteria]: Cranial abnormalities, chronic otitis media with effusion, a prior adenoidectomy or tympanostomy tubes, documented immunological disorders or ongoing antimicrobial prophylaxis for a disease other than AOM | 0–2 | >3/>52
NCT01949142 and NCT01949155 | RCT | Industry | [underlined: Inclusion Criteria] clinical diagnosis of bilateral middle ear effusion requiring tympanostomy tube placement Subject’s caregiver is willing to comply with the protocol and attend all study visits [underlined: Exclusion Criteria] Subject has a history of prior ear or mastoid surgery, not including myringotomy or myringotomy with tympanostomy tube placement Subject has a history of sensorineural hearing loss Subject has a history of chronic or recurrent bacterial infections other than otitis media that likely will require treatment with antibiotics during the course of the study | 0.5–17 | 4/4
Mair 2016 26985629 4/2014–6/2014 U.S. ^28^ | RCT | Industry | [underlined: Key inclusion criteria:] Clinical diagnosis of bilateral MEE requiring TTP, and ability to provide assent for participation in the trial [underlined: Key exclusion criteria] hstory of ear or mastoid surgery; designation for any other surgical procedure that would occur concurrently with TTP; history of sensorineural hearing loss, chronic or recurrent bacterial infections, tympanic membrane perforation, immunodeficiency disease, or abnormality of the tympanic membrane or middle ear; use of topical nonsteroidal otic agents within 1 day of randomization; use of a topical or otic corticosteroid within 3 days of randomization or a systemic corticosteroid within 7 days of randomization; any infection requiring systemic antimicrobial or antifungal agents; use of topical or systemic antimicrobial or antifungal agents before approximate washout intervals; concurrent use of oral anti-inflammatory agents; history of allergy to ciprofloxacin; menarche or postmenarche (among girls); and being the sibling of or residing in the same household as another participan | 0.5–17 | 4/4

RCT: Randomized controlled trial; AOM: acute otitis media; DOB: date of birth; NR: not reported; OME: otitis media with effusion; MEE: middle ear effusion; TTP: tympanostomy tube placement

#### Arm Details

Table 3 shows the arm details information for the studies with both a registry record and papers. Again, the agreement between the record and the data extracted from the papers was, in general, well matched. One record, ISRCTN35793977, indicated a third “watchful waiting” arm that was not reflected in the publication. A second record, NCT00162994, did not provide study arm details, though the resulting paper indicated three arms, tympanostomy tubes, tympanostomy tubes and adenoidectomy, and no treatment.

Table 3 Arm details

Study | Arm description
NCT00365092 | TT inserted promptly
NCT00365092 | TT inserted up to 9 months later if effusion persisted.
Paradise 2001 11309632 | Early TT
Paradise 2001 11309632 | TT six months later if bilateral effusion persisted or nine months later if unilateral effusion persisted
ISRCTN35793977 | TT and adenoidectomy
ISRCTN35793977 | TT
ISRCTN35793977 | Observation and medical management
MRC Multicentre Otitis Media Study Group 2012 (TARGET) 22443163 | TT and adenoidectomy
MRC Multicentre Otitis Media Study Group 2012 (TARGET) 22443163 | TT
ISRCTN57358603 | Early TT
ISRCTN57358603 | Watchful waiting for a period of nine months with analysis by intention to treat
Maw 1999 10459904 | TT within 6 weeks
Maw 1999 10459904 | Watchful waiting for 9 months then TT if needed
NCT00629694 | TT and adenoidectomy
NCT00629694 | Myringotomy and adenoidectomy
Vlastos 2011 21205368 | TT and adenoidectomy
Vlastos 2011 21205368 | Myringotomy and adenoidectomy
NCT00162994 | Procedure: adenoidectomy and tymapanostomy Study arms not provided.
Kujala 2012 22466327 | TT
Kujala 2012 22466327 | TT and adenoidectomy
Kujala 2012 22466327 | No treatment
NCT01949142 and NCT01949155 | OTO-201: One injection of 6 mg OTO-201 (ciprofloxacin in poloxamer 407) into each ear during surgery.
NCT01949142 and NCT01949155 | Sham: Simulated single, intratympanic injection
M air 2016 26985629 | OTO-201: One injection of 6 mg OTO-201 (ciprofloxacin in poloxamer 407) into each ear during surgery.
M air 2016 26985629 | Sham: Simulated single, intratympanic injection

TT: Tympanostomy tubes

#### Risk of Bias

Table 4 shows the risk of bias assessments for the studies, based on the records and the papers. Because of the nature of the records, there was very little data on which to base these assessments, particularly with the ICTRP records, but where the data was adequate the agreement was good. Both ClinicalTrials.gov records indicated the intention to include blinding, but the publications were judged as high risk of bias for this, because they did not explicitly indicate blinding. Likewise, all four records indicated that the trials were randomized controlled trials (RCTs), but none explicitly discussed how randomization would be achieved, so all were rated as unclear based on the criteria used in the original review. Selective reporting bias, group similarity at baseline, and compliance could not be evaluated in the records, as they do not include any information about how the study actually progressed, so those columns have been removed from this table.

Table 4 Risk of bias

Study | Random sequence generation | Allocation concealment | Blinding of participants | Blinding of personnel/care providers | Blinding of outcome assessor | Incomplete outcome data | Intention-to-treat-analysis | Co-interventions | Timing of outcome assessments
ISRCTN35793977 | Unclear | Unclear | High | High | High | Unclear | Unclear | Unclear | Low
MRC Multicentre Otitis Media Study Group 2012 22443163 | High | Unclear | High | High | High | Low | Low | Unclear | Low
ISRCTN57358603 | Unclear | Unclear | High | High | High | Unclear | Low | Unclear | Low
Maw 1999 10459904 | Unclear | Unclear | High | High | High | High | Low | Unclear | Low
NCT00365092 | Unclear | Unclear | Low | High | High | Unclear | Unclear | Unclear | Low
Paradise 2001 11309632 | Low | Low | High | High | High | Low | Low | Unclear | Low
NCT00629694 | Unclear | Unclear | High | High | Unclear | Unclear | Unclear | Low | Low
Vlastos 2011 21205368 | Low | Unclear | High | High | Unclear | High | Low | Low | Low
NCT00162994 | Unclear | Unclear | Low | Unclear | Low | Unclear | Unclear | Unclear | Low
Kujala 2012 22466327, 24445832 | Low | Low | High | High | High | Low | Low | Unclear | Low
NCT01949142 and NCT01949155 | Unclear | Low | Low | Low | Low | Unclear | Low | Unclear | Low
M air 2016 26985629 | Low | Low | Low | Low | Low | Low | Low | Low | Low

#### Outcomes

Overall, the outcomes appeared to match across the records and studies with a few exceptions. In four cases, there were more outcomes listed in the records than reported in the papers, indicating possible selective reporting bias for these studies. This is particularly notable because all of these records were retrospectively entered. In general, the results not reported were quality of life outcomes (See bolded text in Table 5), though the Vlastos record (NCT00629694)^25^ called for secondary tympanogram outcomes that were not reflected in the paper. The exception is the Paradise study, which across four papers reported on more quality of life measures than were called for in the record.

Table 5 Outcomes

Study | Outcomes
NCT00365092 | Auditory continuous performance test Child Behavior Checklist Children’s version of the Hearing in Noise Test Comprehensive Test of Phonological Processing Disruptive Behavior Disorders Rating Scale Impairment Rating Scales Number of words in a grade-level passage read correctly in one minute Visual continuous performance test Wechsler Abbreviated Scale of Intelligence Woodcock Reading Mastery Tests-Revised-Normative Update Woodcock-Johnson III Tests of Achievement, Standard Battery
Paradise 2001 11309632 | Auditory Continuous Performance Test Child Behavior Checklist Children’s Version of the Hearing in Noise Test Comprehensive Test of Phonologial Processing Disruptive Behavior Disorders Rating Scale Impairment Rating Scales McCarthy General Cognitive index McCarthy Verbal Subscale Mean Length of Utterance in Morphemes Nonword repetition test Number of Different Words Oral Reading Fluency Test Parenting Stress Index Peabody Picture Vocabulary Test–Revised Percentage of Consonants Correct–Revised Screening Test for Auditory Processing Disorders Social Skills Rating System Visual Continuous Performance Test Wechsler Intelligence Scale for Children Woodcock Reading Mastery Tests Woodcock-Johnson III Tests of Achievement
ISRCTN35793977 | Behavioral assessment Economic impact General health Hearing Quality of life
MRC Multicentre Otitis Media Study Group 2012 (TARGET) 22443163 | Hearing
ISRCTN57358603 | Behavioral difficulty Hearing
Maw 1999 10459904 | Behavioral difficulty Expressive language Hearing Middle ear effusion Verbal comprehension
NCT00629694 | [underlined: Primary:] OM-6 burden of disease [underlined: Secondary:] Tympanogram type B
Vlastos 2011 21205368 | OM-6 burden of disease
NCT00162994 | [underlined: Primary:] Number of acute otitis media episodes Quality of life [underlined: Secondary:] Number of days of middle ear effusion Speed of recovery of each otitis media episode Time to first recurrence
Kujala 2012 22466327, 24445832 | Number of acute otitis media episodes Time to first recurrence
NCT01949142 and NCT01949155 | [underlined: Primary] Treatment failures defined as the occurrence of any of the following events: otorrhea as determined by a blinded assessor on or after 3 days post-surgery, otic or systemic antibacterial drug use for any reason any time post-surgery, as well as patients who missed visits or were lost-to-follow-up. [underlined: Secondary] Adverse events, otoscopic exams, audiometry, and tympanometry Microbiological response
Mair 2016 26985629 | Treatment failure: (1) the presence of postoperative otorrhea in one or both ears during the visual external ear examination on or after 3 postoperative day (day4); (2) the patient received otic antibiotic drops any time after surgery and before otorrhea confirmation by the blinded assessor; (3) the patient received a systemic antibiotic any time after surgery and before confirmation of otorrhea by the blinded assessor; (4) loss to follow-up; or (5) the patient did not return to the clinic for a blinded assessment Treatment-emergent adverse events (TEAEs), otoscopy for the presence of bilateral effusion, audiometric testing, tympanometry, evaluation of tube occlusion, physical examination, and vital sign measurement

Bold indicates an outcome not in the other source.

#### Studies Containing Results

One record contained results and could be matched to a paper (NCT01949142). Table 6 shows the baselines that were reported in both the record and the paper. The record gave far less baseline information than the paper, but what was reported matched exactly. Results that were reported in both the record and the paper are in Table 7. Again, the paper gave much more detail and included statistical analyses not reported in the record, but the limited information given for the efficacy outcomes of interest matched exactly between the paper and the record. The adverse event results were harder to correlate, because they were reported very differently in the record and the resulting paper. In general, there were few serious adverse events and many other adverse events. The paper reported higher numbers for all types of adverse events than did the record, and both consistently showed more adverse events in the intervention group.

Table 6 Baselines

Study | Arm (N) | Age (y), mean (SD) | Male gender n/N (%)
NCT01949142 | OTO-201 (179) | 2.392 (2.0710) | 104/179 (58.1)
NCT01949142 | Sham (87) | 2.463 (2.1176) | 56/87 (64.4)
Mair 2016 26985629 | OTO-201 (179) | 2.4 (2.1) | 104/179 (58.1)
Mair 2016 26985629 | Sham (87) | 2.5 (2.1) | 56/87 (64.4)

Table 7 Results

Study | Outcome | Timepoint | Arm (N) | Percentage
NCT01949142 | Percentage of Participants Who Were Treatment Failures | Day 15 | OTO-201 (179) | 24.6
NCT01949142 | Percentage of Participants Who Were Treatment Failures | Day 15 | Sham (87) | 44.8
Mair 2016 26985629 | Percentage of Participants Who Were Treatment Failures | Day 15 | OTO-201 (179) | 24.6 (44/179)
Mair 2016 26985629 | Percentage of Participants Who Were Treatment Failures | Day 15 | Sham (87) | 44.8 (39/87)
NCT01949142 | Audiometry Patent tubes | Day 29 | OTO-201 (179) | 98.3 (left ear), 96.0 (right ear)
NCT01949142 | Audiometry Patent tubes | Day 29 | Sham (87) | 94.1 (left ear), 96.5 (right ear)
Mair 2016 26985629 | Audiometry Patent tubes | Day 29 | OTO-201 (179) | At least 94%
Mair 2016 26985629 | Audiometry Patent tubes | Day 29 | Sham (87) | At least 94%

## Relevant Studies Identified via Registry Searches and Not Found in Original Review

Of the 27 records found, 22 did not have a corresponding publication in the original review. Of these, two contained results, and 20 did not.

### Studies Containing Results

Two records contained results, but had no matching reports in the published literature. One (NCT01404611) is noted in the registry as having been completed in 2013. It is likely that a publication of these results is forthcoming. The second (NCT01908803) is noted as having been terminated by management decision in 2014. Both studies address Key Question 5: Treatments for in-tube otorrhea. Both studies are industry funded. Details are in Table 8. Risk of bias assessments are in Table 9. In general, the records did not provide sufficient information to make judgments on risk of bias, but where sufficient information was reported, the risk of bias was generally low.

Table 8 Effectiveness of various interventions to treat TT Otorrhea

Study | Intervention Details | Responders | N
NCT01404611 | DF289 (ciprofloxacin 0.3%) ear drops | NR | 104
NCT01404611 | DF277 (fluocinolone acetonide 0.025%) ear drops | NR | 89
NCT01404611 | DF289 (ciprofloxacin 0.3%) + DF277 (fluocinolone acetonide 0.025%) ear drops | NR | 106
NCT01908803 | AL-60371 (finafloxacin 0.3%)/AL-817 (dexamethasone) otic suspension (200 μL in affected ear(s) through tympanostomy tube on Day 1) | 15 | 39
NCT01908803 | Ciprofloxacin 0.3%/dexamethasone 0.1% otic suspension (Four drops in affected ear(s) twice daily through tympanostomy tube for 7 days) | 7 | 22

NR: not reported

Table 9 Risk of bias of new studies

Study | Random sequence generation | Allocation concealment | Blinding of participants | Blinding of personnel/care providers | Blinding of outcome assessor | Incomplete outcome data | Intention-to-treat-analysis | Co-interventions | Timing of outcome assessments | Selective reporting bias | Group similarity at baseline | Compliance
NCT01404611 | Unclear | Unclear | Low | Low | Low | Low | Unclear | Unclear | Low | Low | Unclear | Unclear
NCT01908803 | Unclear | Unclear | High | High | Low | Low | Low | Unclear | Low | High | Unclear | Unclear

NCT01404611 gives results for 330 patients for time to cessation of otorrhea and adverse events up to 22 days. The adverse events reported include: mastoiditis, respiratory syncytial virus infection, otorrhea, pyrexia, upper respiratory tract infection, nasopharyngitis, and cough.

NCT01908803 gives results for 68 patients for proportion of subjects with sustained clinical cure at day 3 visit and adverse events, including serious adverse events (not defined), other adverse events (not defined), and acute OME.

NCT01404611 indicates that ciprofloxacin and fluocinolone acetonide have the shortest time to cessation of otorrhea (median 4.94 days, 95% CI 3.74 to 5.52), when compared to ciprofloxacin alone (median 6.83 days, 95% CI 5.49 to 7.74) or fluocinolone acetonide alone (median 22 days, 95% CI 13.93 to 22). However, because these are time-to-event data, we would need hazard ratios to perform a meta-analysis and the record does not include any formal statistical comparison. Thus, we were unable to compare these results with the analysis for this key question in the original review. NCT01908803 gives no results for this outcome, citing the early termination of the study.

NCT01908803 indicates that similar percentages had a sustained clinical cure at day 3. The group that got finafloxacin and dexamethasone had a cure rate of 38.5 percent, and the ciprofloxacin and dexamethasone arm a cure rate of 31.8 percent. No statistical analysis is provided, and because these are the same treatment types (antibiotic and glucocorticoid drops), we were not able to add it to our network meta-analysis for this outcome in the original review. The study record indicates that proportion of subjects with microbiological success at the day 8 visit was an outcome of interest, but gives no results for this outcome, citing the early termination of the study. NCT01404611 gives no results for either of these outcomes.

#### Studies Without Results

Twenty studies were identified with no results and no related publications. Fourteen of these were listed in clinicaltrials.gov and therefore had an estimated completion date; ICTRP does not require this. Four of the 14 ClinicalTrials.gov records indicated terminated studies (one with no reason given, two as a management decision, and one because of a change in FDA guidance). Five records indicated active studies with completion dates in the future, and five indicated active status but have a completion date in the past. Of these five, three apparently related records were identified in ClinicalTrials.gov and reported completion dates between 2008 and 2009, one was a cohort study that was supposed to be completed in June 2013, and the last was an RCT with a completion date in September 2015. It is possible that one or both of these studies will be published in the near future. The six studies identified through ICTRP were all noted as ongoing, with first enrollment dates ranging from 2006 to 2014.

### Studies Included in the Original Review with No Registry Record

The original review’s 178 publications addressed five key questions:

Question 1 For children with chronic otitis media with effusion, what is the effectiveness of tympanostomy tubes, compared to watchful waiting, on resolution of middle ear effusion, hearing and vestibular outcomes, quality of life and other patient-centered outcomes?
  a. What factors (such as age, age of onset, duration of effusion, comorbidities, and sociodemographic risk factors) predict which children are likely to benefit most from the intervention?
  b. Does obtaining a hearing test help identify which children are more likely to benefit from the intervention?
Question 2 For children with recurrent acute otitis media, what is the effectiveness of tympanostomy tubes, compared to watchful waiting with episodic or prophylactic antibiotic therapy, on the frequency and severity of otitis media, quality of life, and other patient centered-outcomes? What factors (such as age, age of onset, number of recurrences, presence of persistent middle ear effusion, comorbidities, and sociodemographic risk factors, history of complications of acute otitis media, antibiotic allergy or intolerance) identify children who are most likely to benefit from the intervention?
Question 3 What adverse events, surgical complications, and sequelae are associated with inserting tympanostomy tubes in children with either chronic otitis media with effusion or recurrent acute otitis media?
Question 4 Do water precautions reduce the incidence of tympanostomy tube otorrhea, or affect quality of life?
Question 5 In children with tympanostomy tube otorrhea, what is the comparative effectiveness of topical antibiotic drops versus systemic antibiotics or watchful waiting on duration of otorrhea, quality of life, or need for tube removal?

Of the total 172 studies not found in either registry 75 were published before the inception of ClinicalTrials.com in 2000 and ICTRP in 2005 and thus cannot be expected to be in the registries. No nonrandomized studies were found in the registry searches. Six of 54 RCTs in the report were found in the registries: four for key question 1, one RCT for key question 2, and one for Key Question 5. No studies were identified for key questions 3 or 4. In looking at the 48 RCTs that were included in the report but not found in the registry searches, 35 would not have been expected in ClinicalTrials.gov for the following reasons: 22 had enrollment or publication dates that predated ClinicalTrials.gov’s 2000 launch date, and 13 were not U.S. studies. A search of the MEDLINE records of the studies included in the report did not identify any records that were not identified in the CT.gov or ICTRP searches.