# References

1 Duval S, Tweedie, R. Trim and fill: A simple funnel-plot-based method of testing and adjusting for publication bias in meta-analysis. Biometrics. 2000 Jun;56(2):455–63. PMID: 10877304.10877304
2 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997 Sep 13;315(7109):629–34. PMID: 9310563.9310563
3 Harbord RM, Egger M, Sterne JA. A modified test for small-study effects in meta-analyses of controlled trials with binary endpoints. Stat Med. 2006 Oct 30;25(20):3443–57. doi: 10.1002/sim.2380. PMID: 16345038.16345038
4 Rucker G, Carpenter JR, Schwarzer G. Detecting and adjusting for small-study effects in meta-analysis. Biom J. 2011 Mar;53(2):351–68. doi: 10.1002/bimj.201000151. PMID: 21374698.21374698
5 Copas J, Shi JQ. Meta-analysis, funnel plots and sensitivity analysis. Biostatistics. 2000 Sep;1(3):247–62. doi: 10.1093/biostatistics/1.3.247. PMID: 12933507.12933507
6 Copas J, Shi JQ. A sensitivity analysis for publication bias in systematic reviews. Stat Methods Med Res. 2001 Aug;10(4):251–65. PMID: 11491412.11491412
7 Hedges L, Vevea J. Estimating effect size under publication bias: small sample properties and robustness of a random effects selection model. Journal of Educational and Behavioral Statistics. 1996;21(4):299–332.
8 Chan AW, Hrobjartsson A, Haahr MT, . Empirical evidence for selective reporting of outcomes in randomized trials: comparison of protocols to published articles. JAMA. 2004 May 26;291(20):2457–65. doi: 10.1001/jama.291.20.2457. PMID: 15161896.15161896
9 Roest AM, de Jonge P, Williams C, . Reporting Bias in Clinical Trials Investigating the Efficacy of Second-Generation Antidepressants in the Treatment of Anxiety Disorders: A Report of 2 Meta-analyses. JAMA Psychiatry. 2015 May 1;72(5):500–10. doi: 10.1001/jamapsychiatry.2015.15. PMID: 25806940.25806940
10 Vedula SS, Bero L, Scherer RW, Dickersin K. Outcome reporting in industry-sponsored trials of gabapentin for off-label use. N Engl J Med. 2009 Nov 12;361(20):1963–71. doi: 10.1056/NEJMsa0906126. PMID: 19907043.19907043
11 Vedula SS, Li T, Dickersin K. Differences in reporting of analyses in internal company documents versus published trial reports: comparisons in industry-sponsored trials in off-label uses of gabapentin. PLoS Med. 2013;10(1):e1001378. doi: 10.1371/journal.pmed.1001378. PMID: 23382656.23382656
12 Shirkey H. Therapeutic orphans. Pediatrics. 1999 Sep;104(3 Pt 2):583–4. PMID: 10469793.10469793
13 Anderson ML, Chiswell K, Peterson ED, . Compliance with results reporting at ClinicalTrials.gov. N Engl J Med. 2015 Mar 12;372(11):1031–9. doi: 10.1056/NEJMsa1409364. PMID: 25760355.25760355
14 Milne CP, Davis J. The pediatric studies initiative: after 15 years have we reached the limits of the law? Clin Ther. 2014 Feb 1;36(2):156–62. doi: 10.1016/j.clinthera.2013.11.007. PMID: 24529287.24529287
15 Steele D. Tympanostomy Tubes in Children Protocol. Rockville, MD: Agency for Healthcare Research and Quality; 2015. https://effectivehealthcare.ahrq.gov/ehc/products/617/2147/tympanostomy-tubes-protocol-151116.pdf.
16 Glanville JM, Duffy S, McCool R, Varley D. Searching ClinicalTrials.gov and the International Clinical Trials Registry Platform to inform systematic reviews: what are the optimal search approaches? J Med Libr Assoc. 2014 Jul;102(3):177–83. doi: 10.3163/1536-5050.102.3.007. PMID: 25031558.25031558
17 Tse T, Johnson S, Ripple A. Update: Expanded ClinicalTrials.gov Search Capabilities. NLM Technical Bulletin. 2002 Jul.–Aug.;327(35).
18 Paradise JL, Campbell TF, Dollaghan CA, . Developmental outcomes after early or delayed insertion of tympanostomy tubes. N Engl J Med. 2005 Aug 11;353(6):576–86. doi: 10.1056/NEJMoa050406. PMID: 16093466.16093466
19 Paradise JL, Dollaghan CA, Campbell TF, . Otitis media and tympanostomy tube insertion during the first three years of life: developmental outcomes at the age of four years. Pediatrics. 2003 Aug;112(2):265–77. PMID: 12897272.12897272
20 Paradise JL, Feldman HM, Campbell TF, . Effect of early or delayed insertion of tympanostomy tubes for persistent otitis media on developmental outcomes at the age of three years. N Engl J Med. 2001 Apr 19;344(16):1179–87. doi: 10.1056/nejm200104193441601. PMID: 11309632.11309632
21 Paradise JL, Feldman HM, Campbell TF, . Early versus delayed insertion of tympanostomy tubes for persistent otitis media: developmental outcomes at the age of three years in relation to prerandomization illness patterns and hearing levels. Pediatr Infect Dis J. 2003 Apr;22(4):309–14. doi: 10.1097/01.inf.0000059764.77704.55. PMID: 12690269.12690269
22 Paradise JL, Feldman HM, Campbell TF, . Tympanostomy tubes and developmental outcomes at 9 to 11 years of age. N Engl J Med. 2007 Jan 18;356(3):248–61. doi: 10.1056/NEJMoa062980. PMID: 17229952.17229952
23 Adjuvant adenoidectomy in persistent bilateral otitis media with effusion: hearing and revision surgery outcomes through 2 years in the TARGET randomised trial. Clin Otolaryngol. 2012 Apr;37(2):107–16. doi: 10.1111/j.1749-4486.2012.02469.x. PMID: 22443163.22443163
24 Maw R, Wilks J, Harvey I, . Early surgery compared with watchful waiting for glue ear and effect on language development in preschool children: a randomised trial. Lancet. 1999 Mar 20;353(9157):960–3. doi: 10.1016/s0140-6736(98)05295-7. PMID: 10459904.10459904
25 Vlastos IM, Houlakis M, Kandiloros D, . Adenoidectomy plus tympanostomy tube insertion versus adenoidectomy plus myringotomy in children with obstructive sleep apnoea syndrome. J Laryngol Otol. 2011 Mar;125(3):274–8. doi: 10.1017/s0022215110002549. PMID: 21205368.21205368
26 Kujala T, Alho OP, Kristo A, . Quality of life after surgery for recurrent otitis media in a randomized controlled trial. Pediatr Infect Dis J. 2014 Jul;33(7):715–9. doi: 10.1097/inf.0000000000000265. PMID: 24445832.24445832
27 Kujala T, Alho OP, Luotonen J, . Tympanostomy with and without adenoidectomy for the prevention of recurrences of acute otitis media: a randomized controlled trial. Pediatr Infect Dis J. 2012 Jun;31(6):565–9. doi: 10.1097/INF.0b013e318255ddde. PMID: 22466327.22466327
28 Mair EA, Park AH, Don D, . Safety and Efficacy of Intratympanic Ciprofloxacin Otic Suspension in Children With Middle Ear Effusion Undergoing Tympanostomy Tube Placement: Two Randomized Clinical Trials. JAMA Otolaryngol Head Neck Surg. 2016 May 1;142(5):444–51. doi: 10.1001/jamaoto.2016.0001. PMID: 26985629.26985629
29 De Oliveira GS, Jr., Jung MJ, McCarthy RJ. Discrepancies Between Randomized Controlled Trial Registry Entries and Content of Corresponding Manuscripts Reported in Anesthesiology Journals. Anesth Analg. 2015 Oct;121(4):1030–3. doi: 10.1213/ane.0000000000000824. PMID: 26378702.26378702
30 Norris SL, Holmer HK, Fu R, . Clinical trial registries are of minimal use for identifying selective outcome and analysis reporting. Res Synth Methods. 2014 Sep;5(3):273–84. doi: 10.1002/jrsm.1113. PMID: 26052852.26052852
31 Page MJ, McKenzie JE, Kirkham J, . Bias due to selective inclusion and reporting of outcomes and analyses in systematic reviews of randomised trials of healthcare interventions. Cochrane Database Syst Rev. 2014(10):Mr000035. doi: 10.1002/14651858.MR000035.pub2. PMID: 25271098.25271098
32 Rosenthal R, Dwan K. Comparison of randomized controlled trial registry entries and content of reports in surgery journals. Ann Surg. 2013 Jun;257(6):1007–15. doi: 10.1097/SLA.0b013e318283cf7f. PMID: 23478520.23478520