# Methods

## Overview

This report is based on a systematic review that is currently being conducted by our EPC on the relationship between tympanostomy tubes and a variety of outcomes, including hearing, developmental outcomes and quality of life, adverse events, and otorrhea. The ongoing systematic review (hereafter referred to as “original review”) is being conducted in accordance to IOM standards and AHRQ guidance.

## Terminology

We use the term study to refer to the conducted research. Information about the design or results of studies may be reported in publications or in registry records. It is possible that studies identified through the registry search have no associated publications; and that studies identified in the original review have no records in ClinicalTrials.gov or ICTRP.

## Registry Searches

Because the registry databases are not indexed, queries can only include text words. Thus, it was necessary to translate the search of the original review, which includes text words, as well as controlled-vocabulary (MeSH) terms, to a semantically equivalent query using the ClinicalTrials.gov and ICTRP interfaces. The ClinicalTrials.gov search interface allows only for queries with a limited number of characters, and documentation on advanced searching options, such as truncation and adjacency searching, is sparse.^16, 17^ We were able to keep the PubMed search strategy intact for the ClinicalTrials.gov search, merely translating MeSH terms to text words. However, to run the search in the ICTRP interface, which does not allow for nested queries, we were forced to search only on intervention terms. Appendix A includes the literature searches from the original review and the specific search strategies to be used in ClinicalTrials.gov and ICTRP.

## Analysis

Registry searches were categorized as follows (1) included in the original review but not found in the registry, (2) included in the original review and found in a registry but with no new results data, (3) included in the original review and found in a registry with new data, and (4) identified via the registry but not found in the original review. Though we planned to document rationale for study discontinuation, none were provided for studies included in our analysis. We focus on the value of results data identified via registry searches, and thus highlight the congruence, or lack thereof, among data identified via the registry and found in the original review in light of additional study data identified via registry searches.

For studies included in the original review that also have a registry record, the additional information in the registry records pertains to their design (if the registry record includes protocol information) or their findings (if the record includes results). Information found in records was examined against information obtained from publications to judge whether important changes in the analysis plan occurred. We made such comparisons only with respect to 1) general design items used to inform risk of bias assessments and 2) the analysis plan of the eligible exposure-outcome relationships. The risk of bias of each study result in the original review will be evaluated based on predefined questions. We assessed whether the additional information in the registry records changed the risk of bias assessments in the original review. In the assessment for changes in the analysis plan, we looked for changes in the population studied, the effect measure (e.g., difference in means, odds ratios for specific categorizations of continuous outcomes), and maximum follow up recorded; we also looked for differences in the estimation procedure (the prescribed statistical learning procedure) and the plan for handling missing values, where the records give sufficient information.

We have described whether registry records and publications describe the same outcomes. Because no records with matched publications gave results, we were unable to assess whether the results agreed. Registry records of newly identified studies not included in the original review are summarized in narrative form and extracted into spreadsheets based on the original review’s extraction form. We applied the same risk of bias assessments as in the original review, where it is possible to assess risk of bias, and report results, as well as whether the new results can be incorporated into the analyses of the original review.

## Risk of Bias for the Evidence Base and Strength of Evidence

For outcomes with new data from the registries, we have reassessed the risk of bias of the evidence base and the strength of evidence using the same methodology used for the original review. We assess whether the new studies fall within the range of the similar studies from the original review and whether the additional data are likely to directly impact the strength of evidence or the assessment of risk of bias for the evidence-base.