# Discussion

## Summary of Findings

### Relevant Studies Identified via Registry Searches and Found in Original Review

Six studies were identified in both the registries and the original review. Overall the agreement for design and arm information was very close, as in the one record that reported it is the agreement for baselines and results.

Prespecified outcomes in almost all of the records differed from the outcomes in the publications based on those records. Several other studies have reported on discrepancies between prespecified outcomes in registry records and the resulting published studies. ^29–32^ We did not find any new information in any of these records that would change our initial meta-analyses, risk of bias, or strength or evidence assessments.

### Relevant Studies Identified via Registry Searches and Not Found in Original Review

Twenty studies were screened in via registry searches but not found in the original review. Two gave results, but we were unable to incorporate them in to the analysis, due to the fact that they had no statistical analyses. The results of these trials did not change our initial meta-analyses, risk of bias, or strength or evidence assessments. Seven of the records without results indicate studies with completion dates in the future or recent past. The information about these studies can be used to inform future research needs.

### Studies Included in the Original Review with No Registry Record

We were able to find a registry record for only four of the 178 studies in the original review. The records we found were all for RCTs that addressed key questions 1 and 2.

## Process Limitations

Despite the relative ease of conducting registry searches in our study, the searches yielded no new information that would change our initial risk of bias or strength or evidence assessments. When available, study design, baselines, adverse events reporting, and results reported in the registry and publication typically aligned. Data identified via registry searches generally provided insufficient evidence to make judgments on specific risk of bias items. It was also difficult to draw any conclusions about publication bias based on our analyses.

Study outcomes information had highest number of discrepancies, potentially indication selective reporting bias. However, because many of these studies are relatively recent, it is also possible that information on these outcomes has not been published yet, but will be, indicating time lag, but not publication, bias

This project has a few limitations. The most significant of which is that much of the screening and data extraction was done by a single person, which means that it is possible that studies were missed or data incorrectly extracted. However, the results have been checked against those of the original review and reviewed by the project lead on that report, as well as double-checked in places by other members of the team.

## Conclusion

Our study demonstrated that the EPC systematic review process was amenable to adaptions required for searching, abstracting, and analyzing registry search yields. We used a very broad search and screened out a large number of records, requiring more staff time than is spent on registry searching for typical EPC systematic reviews. More precise searching may reduce associated study costs and sensitivity of the search. In general, we found that registry records were easy to screen and extract – often easier than the resulting publications. Study design and interventions information was readily identifiable and in almost all cases matched that of the papers. However, the patient-level information (baselines and outcomes) was limited in scope and detail. The addition of individual patient data to these records could be very valuable

This project yields limited evidence on the utility of searching ClinicalTrials.gov, because only six records were found that matched papers in the report, along with two others that yielded new results. Based on the evidence we found, there does not appear to be an impact on the conclusions or strength of evidence in the report of including records from ClinicalTrials.gov and ICTRP.

One way in which conducting a registry search is of value to a systematic review project is in identifying ongoing research, as well as gaps in knowledge, and facilitating prioritization of future research to reduce redundancy. Several of the studies not found in the original review but identified through registry searches were unfinished or in progress at the time of the search, these studies should be taken in to account when evaluating the state of the literature and calling for future research.