# Background and Objectives

As described in our Omega-3 Fatty Acids and Cardiovascular Disease report, Systematic reviewers have pursued two methods approaches for dealing with information bias: (1) detecting (and correcting results for) information bias using only the identified studies (e.g., using funnel-plot based methods^1–4^ or various selection models^5–7^) and (2) examining trial registries, surveying researchers, and perusing the grey literature to identify unpublished study results or ongoing studies. Empirical analyses of prospective registry data can inform on the time between study completion and publication, the number of unpublished studies, the fidelity of studies to registered protocols, and the congruence of study results between result registries and publications.^8–11^

Despite efforts to spur pediatric research, children remain “therapeutic orphans” ^12^ for whom a paucity of pediatric-specific research data is available to guide clinical decision making. Searching the grey literature improves the identification of evidence not found in the peer-reviewed literature and may prove particularly valuable for pediatric research synthesis. Empirical evidence suggests that FDA regulated and/or industry sponsored research are more likely to be found in trial registries, but compliance with mandated ClinicalTrials.gov requirements remains poor, including low rates of timely registration and posting of results.^13^ Efforts to incentivize pediatric research have resulted in modest impact toward increasing available data on pediatric drugs and devices.^14^ Studies conducted outside the United States may not be registered with ClinicalTrials.gov but may be found in a local registry (e.g., ICTRP). For these reasons, we propose to search and evaluate studies from both sources.

The objective of this methodology report is to examine the feasibility and additional utility—in terms of impact on risk of bias and strength of evidence assessments—of comprehensive searches of the ClinicalTrials.gov and ICTRP registries to supplement the evidence identified in an ongoing systematic review on tympanostomy tubes in children with otitis media conducted by the Brown Evidence-based Practice Center (EPC).^15^