# Appendix A Search Strategy

## ClinicalTrials.gov search 2/9/16

Note, with the n-3 project, we searched very broadly and spent a lot of time screening out irrelevant abstracts. In this search, I am going to use clinicaltrials.gov’s advance search features to limit the scope of the search.

In Interventions: tympanostomy OR grommet OR grommets OR tube OR tubes OR ventilation OR t-tube OR tubulation OR otologic surgical procedures

In Conditions: otitis OR “glue ear” OR middle ear OR OME OR SOM OR AOM

Limit to child

71 records retrieved

Searching the basic interface with the same terms:

(tympanostomy OR grommet OR grommets OR tube OR tubes OR ventilation OR t-tube OR tubulation OR otologic surgical procedures) AND (otitis OR “glue ear” OR middle ear OR OME OR SOM OR AOM)

Not limited to adults.

133 records retrieved

36 were labeled adult or adult/senior

26 remaining non-overlapping (any relevant?)

## WHO ICTRP search 2/9/16

(tympanostomy OR grommet OR grommets OR tube OR tubes OR ventilation OR t-tube OR tubulation OR otologic surgical procedures) in the intervention

AND

(otitis OR “glue ear” OR middle ear OR OME OR SOM OR AOM) in the condition

Select recruitment status as ALL

Select all countries under countries of recruitment

Does not work

Had to search only on the condition:

otitis OR “glue ear” OR middle ear OR OME OR SOM OR AOM

retrieved 586 records

## Original report searches

MEDLINE (5/26/15 6553 citations)

### Population

(otitis)

OR

(“glue ear”)

OR

“Otitis Media with Effusion”[Mesh]

OR

“Otitis Media, Suppurative”[Mesh]

OR

“Ear, Middle/secretion”[Mesh]

OR

(middle and ear and (effusion* or infect* or inflame* or disease*))

OR

((OME OR SOM or AOM) AND (otitis OR ear))

OR

((mucoid* AND middle AND ear) OR (mucous AND middle AND ear) OR (seromuc* AND middle AND ear))

AND

### Intervention

tympanostomy

OR

grommet*

OR

((ear or “pressure equalization” or PE or myringotomy or ventilating or ventilation) and (tube or tubes))

OR

“Otitis Media with Effusion/surgery”[mesh]

OR

“Middle Ear Ventilation”[Mesh] OR ((middle AND (ear OR tympanic)) AND (tube or tubes))

OR

“Otologic Surgical Procedures”[Mesh]

OR

T-tube or tubulation