# Results

## Study Selection

As described in the Methods section, we originally planned to include 10 RCTs from each of 10 languages (in addition to English). We had to drop Russian since we could not locate a source of Russian language studies in PDF or HTML file format. For Hebrew, we had only one source of studies in PDF or HTML file format (the journal Harefuah); however none of the files that could be translated included RCTs. Furthermore, we found only eight Hebrew language studies that compared two groups of study participants. Thus we analyzed 88 non-English articles (plus 10 English RCTs); see Appendix B for the list of articles utilized.

## Article Translation

Using Google Translate we were unable to translate 21 articles that met eligibility criteria. These included one each in French, German, and Japanese (1/11, 9 percent), two in Chinese (2/12, 17 percent), three in Korean (3/13, 23 percent), four in Italian (4/14, 29 percent), nine in Hebrew (9/17, 53 percent), but none in Portuguese and Spanish. The failures occurred because Google Translate could not read the PDF or HTML file, and we could not copy out of the PDF file, optical character recognition failed, or Google Translate (or our computers) could not recognize the letters or characters (this occurred most commonly with the Asian languages).

The length of time required to translate articles ranged from seconds (51 of 88 articles, 58 percent) to about 1 hour. Using a rough average of 15 seconds for the articles for which it was coded to take “seconds” to translate, the average time to translate was about 10 minutes. The time-for-translation distributions varied by language (Table 2).

Table 2 Translation time, by language

Articles^*^: | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10
European
French | secs | secs | secs | secs | Secs | secs | secs | 30 min | 45 min | 60 min
German | secs | secs | secs | secs | Secs | secs | secs | secs | 20 min | 20 min
Italian | secs | secs | secs | secs | Secs | secs | secs | secs | secs | 1 min
Portuguese | secs | secs | secs | secs | Secs | secs | secs | secs | secs | 45 min
Spanish | secs | secs | secs | secs | Secs | secs | secs | secs | secs | 15 min
Asian
Chinese | secs | secs | 5 min | 10 min | 10 min | 10 min | 10 min | 10 min | 20 min | 45 min
Japanese | secs | secs | secs | secs | Secs | secs | secs | 20 min | 45 min | 60 min
Korean | 10 min | 10 min | 10 min | 10 min | 10 min | 15 min | 20 min | 45 min | 45 min | 45 min
Other
Hebrew | -- | -- | 30 min | 30 min | 30 min | 30 min | 40 min | 45 min | 45 min | 50 min

min = minute(s); secs = “seconds” (the translation was quick, approximately <1 minute).

* For each language, the duration of time for translation of each article is listed, sorted from shortest to longest time. Those articles coded as taking “seconds” to translate are shaded blue. Those articles that took from 1 to 20 minutes to translate are shaded green. Those that took longer (30–60 minutes) are shaded orange.

In general, the European and Japanese language articles could be translated automatically from their PDF or HTML files without manipulation by the research assistant prior to translation. However, the ease of translation was largely related to the file/text types used by the journals and whether Google Translate could read these directly or not. The extra time required to translate the other articles mainly consisted of iteratively copying blocks of text (paragraphs or columns) from the article into the Google Translate Web site and then copying the translated text into Word documents. We discovered (and were informed by the Chinese speakers among us) that we also needed to remove false line breaks (artifactual breaks not at the end of sentences) in the Asian language articles to allow meaningful translation. Translation of tables was frequently very time consuming as it required a large number of translations of individual row and column headers and formatting in the translated Word document. For numerous articles, particularly those in Hebrew and Asian languages, Google Translate could directly translate the PDF or HTML file, but the resulting file was unreadable because of overlapping text across columns; therefore, manual copying and pasting of these articles had to be done. Since Google Translate attempted to maintain the original formatting and because these written languages are much more compact than English, the English text ran from one column to the next overlapping the text in the second column. Appendix C includes examples of poorly translated articles, including some with modest amounts of overlap. Other issues that we encountered included that Google Translate failed to translate an Italian article on one day but succeeded on a later day; one Korean article could not be read on one computer, but could on another computer; one Spanish PDF could not be read originally but could after it was saved as a tiff file from which another PDF was created; and one German article required removing multiple instances of “” (an optional hyphen) before translation could succeed.

## Data Extraction From Translated Articles

The assessment by the English language data extractors was that extraction from translated articles generally took more time than extraction from an equivalent English language article would have taken. (We did not directly compare extraction times since this would have compared extraction speeds of different extractors more than added extraction time due to translation.) For only six (7 percent) studies did the English extractor think that no extra time was needed because of the translation (one Italian, two Korean, one Portuguese, two Spanish); however, one data extractor may have been much more forgiving than others, since five of these six were extracted by one researcher. For 40 articles (45 percent) “a little” extra time was required and for 42 (48 percent) “a lot” of extra time was required. The languages requiring the most extra time to extract (at least half the articles required “a lot” of extra time), in order of extra time required were Chinese (80 percent “a lot”), German (70 percent), Japanese (70 percent), Korean (50 percent), Hebrew (50 percent). However, for certain Hebrew papers (and possibly papers in other languages), little extra time was needed since the translation was so poor that the extractor quickly determined that data could not be extracted. The four Romance languages (Italian, French, Portuguese, and Spanish) required the least extra time to extract.

Google Translate frequently translated non-European language text into gibberish (e.g., “Ahpthofizivlogy,” “Gyeongjeongmaekgan”) or nonsense text (e.g., “cantharidin poisoning attack erosion are sore,” “the poet tested discretely”).

There was general agreement that data described in the text (e.g., eligibility criteria, study methodology) were much more difficult to extract than data reported in tables and figures (i.e., most results). Descriptions of interventions other than drugs and placebo were much more difficult to extract than drugs.

Many of the Hebrew articles posed a particular challenge, because Google Translate often flipped the direction of numbers. (Though Hebrew is written from right to left, numbers are written from left to right as in English; however, Google Translate usually flipped the direction of all items.) Similarly, the translation of the Asian languages often jumbled sentences with numbers in them such that it could not be determined which numbers matched which items (e.g., “The laboratory values of WBC ≧ 3,000/mm^3^, i ≧ platelets Number 10xlO^4^/mm^3^, 6 ≧ total protein.O g/dL (A/G ≧ 1.0), AST, ALT 100 ≦, ≦ serum creatinine 1.5 mg/d.”

## Comparison of Translated With Original Articles

Figures 1–8 show histograms for each language of the distribution of percent agreement of all extracted items (Figure 1) and of items within different sections (Figures 2–8). For each histogram, the median and interquartile range (IQR) of percent agreement is displayed, along with the percent of items that had ≥80 percent agreement (in the upper right corner of each histogram). The European languages are grouped together in the upper section and the Asian languages in the lower section. The histograms for English articles are displayed separately at the bottom of each figure to use as a reference standard.

Figure 1 Histograms of the percent agreement for all items, by language

There were a maximum of 70 items per study. All histograms are drawn on the same scale, with 10 percentage point wide bars. For each histogram (language), the median and interquartile range (IQR) percent agreement across the 10 trials (8 observational studies in Hebrew) are displayed in the upper left corner. The percentage figure displayed in the upper right corner of each histogram represents the percentage of items for which there were >80 percent agreement (indicated by the vertical dashed line).

Figure 1. Histograms of the percent agreement for all items, by language. This figure displays 10 histograms, one for each non-English language and for English studies. The histograms each show the percent agreement between extractions on the x-axis and the percent of items (with a given range of percent agreement) on the y-axis. For each histogram (language), the median and interquartile range (IQR) percent agreement across the 10 trials (8 observational studies in Hebrew) are displayed. The percentage of items for which there were >80% agreement are also displayed. This figure covers all 70 items analyzed in the data extraction form. For French, the median agreement was 75%; IQR 67, 100; 44% of items had >80% agreement. For Italian, the median agreement was 70%; IQR 60, 90; 41% of items had >80% agreement. For Spanish, the median agreement was 67%; IQR 50, 80; 30% of items had >80% agreement. For Portuguese, the median agreement was 85%; IQR 73, 100; 63% of items had >80% agreement. For German, the median agreement was 82%; IQR 63, 100; 62% of items had >80% agreement. For Hebrew, the median agreement was 60%; IQR 0, 75; 24% of items had >80% agreement. For Japanese, the median agreement was 75%; IQR 50, 83; 45% of items had >80% agreement. For Korean, the median agreement was 75%; IQR 63, 100; 46% of items had >80% agreement. For Chinese, the median agreement was 50%; IQR 25, 57; 8% of items had >80% agreement.

Figure 2 Histograms of the percent agreement for eligibility criteria items, by language

There were a maximum of two such items per study. See legend to Figure 1 and Table 4.

Figure 2. Histograms of the percent agreement for eligibility criteria items, by language. This figure displays histograms organized as in Figure 1. This figure covers the 2 items addressing eligibility criteria. For French, the median agreement was 94%; IQR 89, 100; 100% of items had >80% agreement. For Italian, the median agreement was 76%; IQR 67, 86; 50% of items had >80% agreement. For Spanish, the median agreement was 78%; IQR 75, 80; 50% of items had >80% agreement. For Portuguese, the median agreement was 85%; IQR 70, 100; 50% of items had >80% agreement. For German, the median agreement was 80%; IQR 70, 90; 50% of items had >80% agreement. For Hebrew, the median agreement was 75%; IQR 75, 75; 0% of items had >80% agreement. For Japanese, the median agreement was 42%; IQR 33, 50; 0% of items had >80% agreement. For Korean, the median agreement was 65%; IQR 50, 80; 50% of items had >80% agreement. For Chinese, the median agreement was 42%; IQR 33, 50; 0% of items had >80% agreement.

Figure 3 Histograms of the percent agreement for descriptions of treatment and control items, by language

There were a maximum of 12 such items per study. See legend to Figure 1 and Table 4.

Figure 3. Histograms of the percent agreement for descriptions of treatment and control items, by language. This figure displays histograms organized as in Figure 1. This figure covers the 12 items addressing descriptions of treatment and control items. For French, the median agreement was 80%; IQR 69, 92; 58% of items had >80% agreement. For Italian, the median agreement was 69%; IQR 60, 89; 40% of items had >80% agreement. For Spanish, the median agreement was 83%; IQR 75, 100; 67% of items had >80% agreement. For Portuguese, the median agreement was 78%; IQR 71, 92; 50% of items had >80% agreement. For German, the median agreement was 100%; IQR 82, 100; 92% of items had >80% agreement. For Hebrew, the median agreement was 68%; IQR 55, 78; 25% of items had >80% agreement. For Japanese, the median agreement was 71%; IQR 67, 79; 25% of items had >80% agreement. For Korean, the median agreement was 83%; IQR 75, 100; 64% of items had >80% agreement. For Chinese, the median agreement was 42%; IQR 27, 68; 8% of items had >80% agreement.

Figure 4 Histograms of the percent agreement for study characteristics items, by language

There were a maximum of 4 such items per study. See legend to Figure 1 and Table 4.

Figure 4. Histograms of the percent agreement for study characteristics items, by language. This figure displays histograms organized as in Figure 1. This figure covers the 4 items addressing study characteristics. For French, the median agreement was 79%; IQR 74, 85; 50% of items had >80% agreement. For Italian, the median agreement was 79%; IQR 74, 90; 50% of items had >80% agreement. For Spanish, the median agreement was 84%; IQR 71, 94; 75% of items had >80% agreement. For Portuguese, the median agreement was 90%; IQR 79, 100; 75% of items had >80% agreement. For German, the median agreement was 100%; IQR 94, 100; 100% of items had >80% agreement. For Hebrew, the median agreement was 71%; IQR 65, 75; 0% of items had >80% agreement. For Japanese, the median agreement was 45%; IQR 37, 58; 0% of items had >80% agreement. For Korean, the median agreement was 70%; IQR 65, 75; 25% of items had >80% agreement. For Chinese, the median agreement was 56%; IQR 50, 67; 0% of items had >80% agreement.

Figure 5 Histograms of the percent agreement for study methodology items, by language

There were a maximum of 9 such items per study. See legend to Figure 1 and Table 4.

Figure 5. Histograms of the percent agreement for study methodology items, by language. This figure displays histograms organized as in Figure 1. This figure covers the 9 items addressing study methodology. For French, the median agreement was 80%; IQR 80, 90; 78% of items had >80% agreement. For Italian, the median agreement was 70%; IQR 60, 90; 33% of items had >80% agreement. For Spanish, the median agreement was 70%; IQR 50, 80; 22% of items had >80% agreement. For Portuguese, the median agreement was 100%; IQR 90, 100; 89% of items had >80% agreement. For German, the median agreement was 90%; IQR 80, 90; 78% of items had >80% agreement. For Hebrew, there were no data. For Japanese, the median agreement was 90%; IQR 90, 90; 100% of items had >80% agreement. For Korean, the median agreement was 80%; IQR 70, 90; 56% of items had >80% agreement. For Chinese, the median agreement was 56%; IQR 44, 67; 0% of items had >80% agreement.

Figure 6 Histograms of the percent agreement for descriptions of outcomes items, by language

There were a maximum of seven such items per study. See legend to Figure 1 and Table 4.

Figure 6. Histograms of the percent agreement for descriptions of outcomes items, by language. This figure displays histograms organized as in Figure 1. This figure covers the 7 items addressing descriptions of outcomes. For French, the median agreement was 67%; IQR 67, 100; 43% of items had >80% agreement. For Italian, the median agreement was 89%; IQR 60, 100; 57% of items had >80% agreement. For Spanish, the median agreement was 80%; IQR 63, 100; 57% of items had >80% agreement. For Portuguese, the median agreement was 88%; IQR 71, 100; 71% of items had >80% agreement. For German, the median agreement was 63%; IQR 57, 80; 29% of items had >80% agreement. For Hebrew, the median agreement was 38%; IQR 0, 100; 33% of items had >80% agreement. For Japanese, the median agreement was 63%; IQR 33, 100; 29% of items had >80% agreement. For Korean, the median agreement was 71%; IQR 33, 100; 43% of items had >80% agreement. For Chinese, the median agreement was 75%; IQR 44, 89; 43% of items had >80% agreement.

Figure 7 Histograms of the percent agreement for categorical results items, by language

There were a maximum of nine such items per study. See legend to Figure 1 and Table 4.

Figure 7. Histograms of the percent agreement for categorical results items, by language. This figure displays histograms organized as in Figure 1. This figure covers the 9 items addressing categorical results. For French, the median agreement was 75%; IQR 67, 100; 33% of items had >80% agreement. For Italian, the median agreement was 0%; IQR 0, 100; 44% of items had >80% agreement. For Spanish, the median agreement was 67%; IQR 50, 67; 0% of items had >80% agreement. For Portuguese, the median agreement was 90%; IQR 50, 100; 63% of items had >80% agreement. For German, the median agreement was 57%; IQR 57, 57; 0% of items had >80% agreement. For Hebrew, the median agreement was 63%; IQR 60, 90; 38% of items had >80% agreement. For Japanese, the median agreement was 80%; IQR 50, 100; 56% of items had >80% agreement. For Korean, the median agreement was 100%; IQR 100, 100; 100% of items had >80% agreement. For Chinese, the median agreement was 57%; IQR 57, 57; 0% of items had >80% agreement.

Figure 8 Histograms of the percent agreement for continuous results items, by language

There were a maximum of 27 such items per study. See legend to Figure 1 and Table 4.

Figure 8. Histograms of the percent agreement for continuous results items, by language. This figure displays histograms organized as in Figure 1. This figure covers the 27 items addressing continuous results. For French, the median agreement was 67%; IQR 50, 100; 26% of items had >80% agreement. For Italian, the median agreement was 67%; IQR 50, 100; 36% of items had >80% agreement. For Spanish, the median agreement was 50%; IQR 0, 60; 0% of items had >80% agreement. For Portuguese, the median agreement was 80%; IQR 67, 100; 55% of items had >80% agreement. For German, the median agreement was 80%; IQR 60, 100; 57% of items had >80% agreement. For Hebrew, the median agreement was 0%; IQR 0, 50; 23% of items had >80% agreement. For Japanese, the median agreement was 75%; IQR 50, 80; 48% of items had >80% agreement. For Korean, the median agreement was 67%; IQR 50, 75; 24% of items had >80% agreement. For Chinese, the median agreement was 25%; IQR 0, 50; 4% of items had >80% agreement.

We evaluated up to 70 extracted items per article (see below for items). The actual number of compared items per article ranged from 10 to 65, with a mean of 39 and a median (IQR) of 41 (34, 45) items. We arbitrarily define “high agreement” to mean there was at least 80 percent agreement within an item or article.

Evaluating all items analyzed together (Figure 1), Portuguese and German articles had the best agreement between original and translated extractions, with high agreement between extractors among about 60 percent of the items. This compared with high agreement in English language agreement for 80 percent of the items. French, Italian, Japanese, and Korean articles had high agreement for about 40 to 45 percent of items. Spanish articles for 30 percent of items, Hebrew articles for 24 percent of items, and Chinese for 8 percent of items. Table 3 shows that the absolute agreement and the percent of items with high agreement were statistically significantly worse for all languages than for English articles. Furthermore, 8 of 10 English language articles had high agreement for all items; compared with similar levels of agreement among Portuguese and German articles, lesser agreement among other languages, and notably, no Chinese articles with high agreement.

Table 3 Agreement across all items, by language

Language | Agreement, Median (IQR) | P^*^ | Items with ≥80% Agreement | P^*^ | Articles with ≥80% Agreement | P^*^
Portuguese | 0.85 (0.73, 1.00) | 0.015 | 40/64 (63%) | 0.032 | 7/10 (70%) | 1.00
German | 0.82 (0.63, 1.00) | 0.001 | 37/60 (62%) | 0.029 | 6/10 (60%) | 0.63
French | 0.75 (0.67, 1.00) | <0.001 | 31/70 (44%) | <0.001 | 4/10 (40%) | 0.17
Korean | 0.75 (0.63, 1.00) | <0.001 | 27/59 (46%) | <0.001 | 4/10 (40%) | 0.17
Japanese | 0.75 (0.50, 0.83) | <0.001 | 29/64 (45%) | <0.001 | 3/10 (30%) | 0.070
Italian | 0.70 (0.60, 0.90) | <0.001 | 26/63 (41%) | <0.001 | 4/10 (40%) | 0.17
Spanish | 0.67 (0.50, 0.80) | <0.001 | 18/61 (30%) | <0.001 | 3/10 (30%) | 0.070
Hebrew | 0.60 (0.00, 0.75) | <0.001 | 9/37 (24%) | <0.001 | 3/8 (37.5%) | 0.15
Chinese | 0.50 (0.25, 0.57) | <0.001 | 5/65 (8%) | <0.001 | 0/10 (10%) | 0.001
English | 1.00 (0.80, 1.00) | ref | 53/66 (80%) | ref | 8/10 (80%) | ref

ref = reference language for statistical test (P value)

* P value versus English

Table 4 displays the list of sections and their respective items that we next analyzed. Tables 5 and 6 display the absolute agreement (Table 5) and the percent of items with high agreement (Table 6) by each section of the data extraction form. Similar patterns hold across languages. Despite the subjective assessment by the data extractors that certain sections were more difficult to extract than others, there were no consistent patterns evident across sections regarding the degree of agreement.

Table 4 Analyzed data extraction items, by section

Section | n | Items
Eligibility criteria | 2 | Inclusion criteria | Exclusion criteria
Description of treatment/control | 12 | Treatment name | Control name
Description of treatment/control | 12 | Treatment description | Control description
Description of treatment/control | 12 | Treatment dose | Control dose
Description of treatment/control | 12 | Treatment frequency | Control frequency
Description of treatment/control | 12 | Treatment route | Control route
Description of treatment/control | 12 | Treatment duration | Control duration
Study characteristics | 4 | Followup duration | Number enrolled
Study characteristics | 4 | Number of centers | Number analyzed
Study methodology | 9 | Blinded patient (Y/N)^*^ | Randomization technique reported (Y/N)^*^
Study methodology | 9 | Blinded caregiver (Y/N)^*^ | Allocation concealment method reported (Y/N)^*^
Study methodology | 9 | Blinded outcome assessment (Y/N)^*^ | Claimed intention-to-treat (Y/N)^*^
Study methodology | 9 | Reported “double blind” (Y/N)^*^ | Power calculation reported (Y/N)^**^
Study methodology | 9 | Reported “single blind” (Y/N)^*^
Outcomes description | 7 | Outcome name (1st outcome) | Outcome name (3rd outcome)
Outcomes description | 7 | Outcome description (1st outcome) | Outcome name (4th outcome)
Outcomes description | 7 | Outcome name (2nd outcome) | Outcome name (5th outcome)
Outcomes description | 7 | Outcome description (2nd outcome)
Dichotomous results | 9 | No. events (treatment arm) | Result/value
Dichotomous results | 9 | No. total (treatment arm) | 95% confidence interval
Dichotomous results | 9 | No. events (control arm) | P value (difference between arms)
Dichotomous results | 9 | No. total (control arm) | Factors adjusted for
Dichotomous results | 9 | Metric reported (e.g., odds ratio)
Continuous results | 27 | Unit of measurement | Measure of variability^†^ (baseline & final) | Value change (treatment)
Continuous results | 27 | No. baseline (treatment) | No. baseline (control) | Variability change (treatment)
Continuous results | 27 | Value baseline (treatment) | Value baseline (control) | P value change (treatment)
Continuous results | 27 | Variability baseline (treatment) | Variability baseline (control) | Value change (control)
Continuous results | 27 | No. final (treatment) | No. final (control) | Variability change (control)
Continuous results | 27 | Value final (treatment) | Value final (control) | P value change (control)
Continuous results | 27 | Variability final (treatment) | Variability final (control) | Factors adjusted for
Continuous results | 27 | Value net difference | Measure of variability^†^ (within-arm change) | Between-arm difference type^‡^
Continuous results | 27 | Variability net difference | Measure of variability^†^ (between-arm difference) | P value (between-arm difference)

* Y/N = yes/no question.

† Standard deviation, standard error, or 95% confidence interval

‡ Difference between final values or net difference

Table 5 Percent of items for which there was agreement, by language and data extraction form section

Section: | Eligibility | (n=2) | Tx/Cx | (n=12) | Study Char | (n=4) | Methods | (n=9) | Outcomes | (n=7) | Dich Res | (N=9) | Cont Res | (n=27)
Language | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P †
Portuguese | 0.85 (0.70, 1.00) | 1.00 | 0.78 (0.71, 0.92) | 0.004 | 0.90 (0.79, 1.00) | 0.77 | 1.00 (0.90, 1.00) | 0.17 | 0.88 (0.71, 1.00) | 0.10 | 0.90 (0.50, 1.00) | 0.70 | 0.80 (0.67, 1.00) | 0.091
German | 0.80 (0.70, 0.90) | 0.68 | 1.00 (0.82, 1.00) | 0.10 | 1.00 (0.94, 1.00) | 0.28 | 0.90 (0.80, 0.90) | 0.58 | 0.63 (0.57, 0.80) | 0.002 | 0.57 (0.57, 0.57) | 0.005 | 0.80 (0.60, 1.00) | 0.084
French | 0.94 (0.89, 1.00) | 0.44 | 0.80 (0.69, 0.92) | 0.005 | 0.79 (0.74, 0.85) | 0.30 | 0.80 (0.80, 0.90) | 0.34 | 0.67 (0.67, 1.00) | 0.027 | 0.75 (0.67, 1.00) | 0.66 | 0.67 (0.50, 1.00) | 0.007
Korean | 0.65 (0.50, 0.80) | 0.22 | 0.83 (0.75, 1.00) | 0.006 | 0.70 (0.65, 0.75) | 0.074 | 0.80 (0.70, 0.90) | 0.20 | 0.71 (0.33, 1.00) | 0.028 | 1.00 (1.00, 1.00) | 0.037 | 0.67 (0.50, 0.75) | 0.007
Japanese | 0.42 (0.33, 0.50) | 0.12 | 0.71 (0.67, 0.79) | 0.001 | 0.45 (0.37, 0.58) | 0.020 | 0.90 (0.90, 0.90) | 0.93 | 0.63 (0.33, 1.00) | 0.019 | 0.80 (0.50, 1.00) | 0.35 | 0.75 (0.50, 0.80) | 0.005
Italian | 0.76 (0.67, 0.86) | 0.44 | 0.69 (0.60, 0.89) | <0.001 | 0.79 (0.74, 0.90) | 0.56 | 0.70 (0.60, 0.90) | 0.038 | 0.89 (0.60, 1.00) | 0.040 | 0.00 (0.00, 1.00) | 0.31 | 0.67 (0.50, 1.00) | 0.024
Spanish | 0.78 (0.75, 0.80) | 0.22 | 0.83 (0.75, 1.00) | 0.025 | 0.84 (0.71, 0.94) | 0.47 | 0.70 (0.50, 0.70) | 0.022 | 0.80 (0.63, 1.00) | 0.034 | 0.67 (0.50, 0.67) | 0.038 | 0.50 (0.00, 0.60) | <0.001
Hebrew | 0.75 (0.75, 0.75) | 0.10 | 0.68 (0.55, 0.78) | 0.002 | 0.71 (0.65, 0.75) | 0.080 | ‡ | ‡ | 0.38 (0.00, 1.00) | 0.033 | 0.63 (0.60, 0.90) | 0.25 | 0.00 (0.00, 0.50) | 0.001
Chinese | 0.42 (0.33, 0.50) | 0.12 | 0.42 (0.27, 0.68) | <0.001 | 0.56 (0.50, 0.67) | 0.041 | 0.56 (0.44, 0.67) | 0.001 | 0.75 (0.44, 0.89) | 0.009 | 0.57 (0.57, 0.57) | 0.003 | 0.25 (0.00, 0.50) | <0.001
English | 0.85 (0.80, 0.90) | ref | 1.00 (1.00, 1.00) | ref | 0.90 (0.80, 0.95) | ref | 0.90 (0.80, 1.00) | ref | 1.00 (1.00, 1.00) | ref | 0.87 (0.70, 1.00) | ref | 1.00 (0.72, 1.00) | ref

“n” refers to the number of items per section.

ref = reference language for statistical tests (P value); Tx/Cx = treatment and control; Study Char = study characteristics; Dich Res = dichotomous results; Cont Res = continuous results.

Red: P≤0.05; yellow: 0.05<P<0.10; blue: P≥0.10.

* Percent agreement among items in section

† P value versus English

‡ These items, related to randomized controlled trials, were not extracted for Hebrew observational studies.

Table 6 Items with at least 80 percent agreement, by language and data extraction form section

Section: | Eligibility | (n=2) | Tx/Cx | (n=12) | Study Char | (n=4) | Methods | (n=9) | Outcomes | (n=7) | Dich Res | (N=9) | Cont Res | (n=27)
Language | ≥80%^*^, #/N (%) | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P † | Median (IQR)^*^ | P †
Portuguese | 1/2 (50%) | 1.00 | 6/12 (50%) | 0.069 | 3/4 (25%) | 1.00 | 8/9 (11%) | 1.00 | 5/7 (29%) | 0.46 | 5/8 (38%) | 1.00 | 12/22 (45%) | 0.55
German | 1/2 (50%) | 1.00 | 11/12 (8%) | 1.00 | 4/4 (0%) | 1.00 | 7/9 (22%) | 1.00 | 2/7 (71%) | 0.021 | 0/5 (100%) | 0.021 | 12/21 (43%) | 0.55
French | 2/2 (0%) | . | 7/12 (42%) | 0.16 | 2/4 (50%) | 1.00 | 7/9 (22%) | 1.00 | 3/7 (57%) | 0.070 | 3/9 (67%) | 0.15 | 7/27 (74%) | 0.005
Korean | 1/2 (50%) | 1.00 | 7/11 (36%) | 0.16 | 1/4 (75%) | 0.49 | 5/9 (44%) | 0.29 | 3/7 (57%) | 0.070 | 5/5 (0%) | 0.49 | 5/21 (76%) | 0.007
Japanese | 0/2 (100%) | 0.33 | 3/12 (75%) | 0.003 | 0/4 (100%) | 0.14 | 9/9 (0%) | 1.00 | 2/7 (71%) | 0.021 | 5/9 (44%) | 0.62 | 10/21 (52%) | 0.24
Italian | 1/2 (50%) | 1.00 | 4/10 (60%) | 0.020 | 2/4 (50%) | 1.00 | 3/9 (67%) | 0.050 | 4/7 (43%) | 0.19 | 4/9 (56%) | 0.34 | 8/22 (64%) | 0.075
Spanish | 1/2 (50%) | 1.00 | 8/12 (33%) | 0.32 | 3/4 (25%) | 1.00 | 2/9 (78%) | 0.015 | 4/7 (43%) | 0.19 | 0/5 (100%) | 0.021 | 0/22 (100%) | <0.001
Hebrew | 0/2 (100%) | 0.33 | 1/4 (75%) | 0.027 | 0/4 (100%) | 0.14 | ‡ | ‡ | 2/6 (67%) | 0.021 | 3/8 (63%) | 0.32 | 3/13 (77%) | 0.017
Chinese | 0/2 (100%) | 0.33 | 1/12 (92%) | <0.001 | 0/4 (100%) | 0.14 | 0/9 (100%) | <0.001 | 3/7 (57%) | 0.070 | 0/5 (100%) | 0.021 | 1/26 (96%) | <0.001
English | 2/2 (0%) | ref | 11/12 (8%) | ref | 3/4 (25%) | ref | 8/9 (11%) | ref | 7/7 (0%) | ref | 6/8 (25%) | ref | 16/24 (33%) | ref

“n” refers to the number of items per section.

ref = reference language for statistical tests (P value); Tx/Cx = treatment and control; Study Char = study characteristics; Dich Res = dichotomous results; Cont Res = continuous results.

Red: P≤0.05; yellow: 0.05<P<0.10; blue: P≥0.10.

* Number and percent of items that had ≥80% agreement in section

† P value versus English

‡ These items, related to randomized controlled trials, were not extracted for Hebrew observational studies.