# References

1 Egger M, Zellweger-Zahner T, Schneider M, et al. Language bias in randomised controlled trials published in English and German. Lancet. 1997;350(9074):326-9. [pmid: 9251637].
2 National Research Council. Finding What Works in Health Care: Standards for Systematic Reviews. Washington, DC. The National Academies Press. 2011.
3 Heres S, Wagenpfeil S, Hamann J, et al. Language bias in neuroscience—is the Tower of Babel located in Germany?. Eur Psychiatry. 2004;19(4):230-2. [pmid: 15196606].
4 Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].
5 Gregoire G, Derderian F, Le LJ. Selecting the language of the publications included in a meta-analysis: is there a Tower of Babel bias?. J Clin Epidemiol. 1995;48(1):159-63. [pmid: 7853041].
6 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. 2002;31(1):115-23. [pmid: 11914306].
7 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. 2000;53(9):964-72. [pmid: 11004423].
8 Morrison A, Moulton K, Clark M, et al. English-language restriction when conducting systematic review-based meta-analyses: systematic review of published studies. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2009.
9 Pham B, Klassen TP, Lawson ML, et al. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005;58(8):769-76. [pmid: 16086467].
10 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
11 Robinson KA, Dickersin K. Development of a highly sensitive search strategy for the retrieval of reports of controlled trials using PubMed. Int J Epidemiol. 2002;31(1):150-3. [pmid: 11914311].
12 Aiken M, Ghosh K, Wee J, et al. An evaluation of the accuracy of online translation systems. Communications of the IIMA. International Information Management Association. http://findarticles.com/p/articles/mi_7099/is_4_9/ai_n56337599/?tag=content. 2009. Accessed January 9, 2012.
13 Aiken M, Balan S. An analysis of Google Translate accuracy. Translation Journal. April. 2011;16(2). http://translationjournal.net/journal/56google.htm. Accessed January 6, 2012.
14 Freitas de Souza R, Sequeira P, Nasser M, et al. Is Google Translate useful for the selection of studies to be included in Cochrane reviews?. 17th Cochrane Colloquium. Singapore. 11–14 October 2009. http://www.imbi.uni-freiburg.de/OJS/cca/index.php?journal=cca&page=article&op=view&path%5B%5D=8037. 2009. Accessed January 30, 2012.
15 Sheppard F. Medical writing in English: The problem with Google Translate. Presse Med. Jun. 2011;40(6:):565-6. Epub 2011 Apr 22. [pmid: 21514783].