# Introduction

Systematic reviews conducted by the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Centers (EPCs) most commonly restrict literature searches to English language publications. In a sample of 10 recent Evidence Reports (numbers 189–198), 8 were restricted to English language publications. One report included studies in languages for which the EPC had “available fluency” and only one reported not restricting by language. Among 28 recent Comparative Effectiveness Review (CER) reports with final or draft documents downloadable from the AHRQ Web site, 20 were restricted to English language publications. Four explicitly did not impose any language restriction. Two did not report language restriction in their methods chapter and included one study each in Dutch and German. One placed no language restriction on comparative studies but included only English language cohort studies. One included German and French language studies for nonoperative interventions (which were sparse), but only English language publications for operative treatments “due to lack of translation resources.” Three of the CERs wrote that the language restriction was due to lack of resources or prohibitive translation costs, despite the recognition in one CER “that requiring studies to be published in English could lead to bias.”

Thus, in most instances, EPC reports are at risk of selection bias based on language1 and may not be following Standard 3.2.6 from the recent Institute of Medicine’s (IOM) Finding What Works in Health Care: Standards for Systematic Reviews,2 “Search for studies reported in languages other than English if appropriate.” The IOM report notes that there is some known evidence of language bias (e.g., investigators in Germany may be more likely to publish their negative results in German language publications and their positive results in English language publications).1,3 However, numerous other studies have found that excluding non-English publications may not result in substantial bias (changes in estimates of treatment effects).4–10 Nevertheless, excluding studies solely based on language runs counter to the concept of systematic review, of including all known evidence, particularly as investigators are being encouraged to include non-peer-reviewed and other studies in the grey literature.

Using a literature search module for randomized controlled trials,11 a search in Medline from 1996 to December 1, 2011 found that of 2,856,102 citations, 92 percent were published in English. Table 1 shows the number and frequency of publications in other languages with at least 1 citation.

Table 1 Percentage of studies from Medline in various languages

Language | N | Percent
Total (1996–2011) | 2,856,102 | 100.00%
English | 2,620,674 | 91.76%
Chinese | 47,604 | 1.67%
German | 38,357 | 1.34%
Russian | 33,732 | 1.18%
French | 28,550 | 1.00%
Spanish | 26,272 | 0.92%
Japanese | 16,444 | 0.58%
Italian | 10,496 | 0.37%
Polish | 10,018 | 0.35%
Portuguese | 7,440 | 0.26%
Danish | 2,516 | 0.09%
Dutch | 2,202 | 0.08%
Czech | 2,071 | 0.07%
Hungarian | 1,707 | 0.06%
Norwegian | 1,646 | 0.06%
Turkish | 1,482 | 0.05%
Swedish | 1,413 | 0.05%
Lithuanian | 954 | 0.03%
Korean | 950 | 0.03%
Finnish | 914 | 0.03%
Bulgarian | 775 | 0.03%
Hebrew | 711 | 0.02%
Slovak | 436 | 0.02%
Icelandic | 77 | <0.01%
Afrikaans | 26 | <0.01%
Greek | 22 | <0.01%
Arabic | 15 | <0.01%
Thai | 5 | <0.01%
Catalan | 3 | <0.01%
Macedonian | 3 | <0.01%
Georgian | 2 | <0.01%
Malay | 2 | <0.01%
Indonesian | 1 | <0.01%
Latvian | 1 | <0.01%

In general, the Tufts EPC restricts to English language publications for its CERs and other reviews for which we expect large volumes of evidence. Even though our EPC includes researchers who are native speakers of several European and Asian languages, we preferentially restrict to English to allow for review and checking of the studies by all team members and also to avoid overburdening nonteam members with translating duties. There was generally consensus among our EPC, our Task Order Officers, and our Technical Expert Panels that including non-English language articles would impose an unnecessary time and resource burden. However, in several instances where the available evidence is of relatively small volume or when we know of important studies in non-English languages, we have gotten data extraction or formal translation done for us.

For a CER we recently conducted, we chose not to apply a language restriction. We ended up including two Spanish language articles. In addition, we needed to review the full text of one French, one Italian, four German, and two Japanese articles. Native German and Japanese speakers were able to screen (and exclude) the latter studies. For the Spanish, French, and Italian studies we tried Google’s Web-based translation services, Google Translate® (http://translate.google.com). The site can translate large quantities of text that are pasted directly into a text box, or it can be configured to automatically translate foreign language Web pages or PDF files. The program can translate 63 languages (from Afrikaans to Yiddish) into English. Our use of the program was highly successful. The French and Italian language articles were translated sufficiently clearly for an American with middling French and tourist Italian to be confident about reasons for exclusion. One Spanish article was translated sufficiently clearly for an American with middling Spanish to be confident about the data extraction. The remaining article had one section that seemed to be translated poorly, but a native Spanish speaker confirmed that the original Spanish was just as incomprehensible as the translation.

EPCs have varying capacities to extract non-English language articles, based on the language knowledge of their staff. Formally translating all non-English language articles is costly and resource-intensive, particularly if performed at the stage of full-text article screening. Therefore, a reliable, free, easily available service to translate articles may allow EPCs to easily broaden the scope of their systematic reviews, without introducing possible language bias by restrictions based on language. Google Translate is a free, Web-based program with an excellent reputation for accurate, natural translation. It is the best known such tool among others, including Yahoo!® Babel Fish (babelfish.yahoo.com), Applied Language® (www.appliedlanguage.com/free_translation.shtml), SDL FreeTranslation® (www.freetranslation.com), and Bing® Translator (www.microsofttranslator.com). In an analysis of four translation tools for a limited set of language pairs, Google Translate was found to perform best based on human judgment of translation accuracy.12 A subsequent study comparing 2550 language pairs (51 languages) in Google Translate using an automated technique to compare translations found a range of translation accuracy and that “translations between European languages are usually good, while those involving Asian languages are often relatively poor. Further, the vast majority of language combinations probably provide sufficient accuracy for reading comprehension in college.”13 Also of note, a pilot study presented as a poster at the 2009 Singapore Cochrane Collaboration meeting used Google Translate on 11 German articles from one Cochrane review and found that interrater agreement was 73 percent (κ=0.38) for whether the article should be included in the review.14

If the translations of the articles are sufficiently accurate for data extraction, the EPCs ought to be able to reliably and easily avoid language restrictions in their reviews. We found only a single article in Medline that considered the use of Google Translate, an editorial focusing on the conceptual problems primary researchers would have translating their manuscripts into English for submission to journals, and advocating for the use of profession translation services.15

## Aims

We conducted a pilot study to formally evaluate the accuracy of one freely available, online, translation tool—Google Translate—for the purposes of data extraction of non-English language articles. We performed simultaneous limited data extraction of a randomly selected convenience sample of recently published non-English language publications and their Google translations. The study was reviewed by the Tufts Health Sciences Campuses Institutional Review Board. It was determined that the activity did not constitute human study research at Tufts University and did not require Institutional Review Board approval.

The research had the following aims:

1. Compare for discrepancies between data extraction done on original-language articles of trials by a native speaker and data extraction done on English-language translations by Google Translate of trials by a researcher who does not know the original article language.
2. Determine the cause of any discrepancies to determine how likely they are to be due to inaccurate translation, and whether there are any clear patterns within, across, or between languages.
3. Track and enumerate the time and resources used for article translation and the extra time and resources required for data extraction related to use of translated articles.