# Acknowledgments

We would like to acknowledge and thank the following highly experienced investigators who extracted non-English language articles. Without their input, this investigation would have been impossible: Johanna Paola Contreras, M.D. MSc, The Zena and Michael A. Wiener Cardiovascular Institute, Mount Sinai School of Medicine, New York, NY; Issa Dahabreh, M.D., M.S., Tufts Evidence-based Practice Center, Tufts Medical Center, Boston MA; Georgios D. Kitsios, M.D. Ph.D., Tufts Evidence-based Practice Center, Tufts Medical Center, Boston MA; Jounghee Lee, Ph.D., Graduate School of Education, Kyonggi University, Seoul, South Korea; Teruhiko Terasawa, M.D., Ph.D., Fujita Health University, School of Medicine, Tsu, Japan; Katrin Uhlig, M.D., M.S., Tufts Evidence-based Practice Center, Tufts Medical Center, Boston MA; and Linjie Zhang, M.D., Maternal and Child Health, Federal University of Rio Grande, Rio Grande do Sul, Brazil.