# Discussion

Our results showed that using Google Translate to translate medical articles in many cases may be feasible and not a resource-intensive process that leads to operationally workable English versions. The accuracy of translation was heavily dependent on the original language of the article. Specifically, Romance languages had much higher levels of agreement than Asian languages and Hebrew. This difference across languages was similar to the findings of machine translation experts for general translation.13

This study had several important limitations. This was a pilot study with a small number of articles extracted in each language, with only a single extractor available for each language. (We did have two extractors for French, but they did not review each other’s extractions.) We were unable to fully ascertain the accuracy of the data extraction in the original languages, which may have resulted in spuriously high rates of disagreement. We were not able to directly attribute disagreement between extractors to errors in translation, as disagreement could also be due to different extractors interpreting articles in different ways or errors in extraction. This effect may have been extractor-dependent, which would have manifested as being language-dependent.

We could not confirm the accuracy of extractions, particularly those done from the original language articles. Data extractors of the translated articles were asked to fill in missing or unclear data, but we were unable to coordinate full determination of why there were disagreements. Therefore, we added a double-extraction of English language articles to use as a reference standard to gauge the degree of disagreement in the translated articles. In addition, while native speakers were chosen to extract the original language articles, these extractors were not always medically trained in their native language. Thus, translations that employed non-English medical terminology may have been difficult to extract from the original articles.

Extractors may or may not have been familiar with the medical topic covered by the article, which is another factor introducing variability to the results. It is likely that the data extraction error rate was higher than for a typical systematic review, since the articles were on random topics and the data extractors were neither trained nor necessarily proficient in the clinical domains. Furthermore, the assessment of whether extractors agreed with each other was inherently subjective for many items.

In addition, our grouping of extraction items into sections was arbitrary and we did not adjust for the relative size or complexity of items within each study. Thus, it might not be appropriate to directly compare across sections. Percent agreement for eligibility criteria (with two items) is conceptually different than percent agreement for continuous outcomes (with 27 items). Thus, the apparent oddity that “results” sections (dichotomous and continuous) had low levels of agreement (e.g., a median of 25 percent for Chinese) may be largely explained by the number and breadth of specific items within these sections.

The Google Translate tool is ever-evolving and presumably improving, as users around the world improve the accuracy of translations. It is also reasonable to assume that with time more articles from more non-English language publications will be in a format that can be directly (and thus quickly) translated. However, this also implies that the accuracy of translations between different pairs of languages will at least partly depend on how many words and documents are being translated among different languages on the Internet. Tricks for more rapid and more accurate translation can also easily be gathered and made available to all the EPCs. Although data extraction from translated articles was assessed to be considerably more difficult and time consuming than extraction from equivalent English language articles, extraction was always feasible in what was considered to be a reasonable amount of time. The exception to this was when articles were so badly translated that it was clear that little usable data could be extracted. This occurred most commonly with Chinese language articles and also with Hebrew articles.

Even though Google translation of medical articles in most cases is far from perfect and on average results in higher levels of inaccuracies than extraction from English, we conclude that for most of the tested languages it may be worth attempting to translate (with Google Translate) and extract non-English language articles that are available as machine-readable PDF (or HTML) files. Based on the fluency and legibility of the translation, the reviewer should be able to make an assessment regarding how much confidence to have in the accuracy of the translated version. It may be appropriate to consistently perform sensitivity analyses regarding translated articles, where possible differences in findings (by meta-analysis) or conclusions (overall) may occur when translated articles are included or omitted. It should be recognized that any differences may be due not only to differences in applicability or methodology, but to errors in translation.

Our anecdotal experience suggests that using Google Translate for articles in languages that an extractor is at least somewhat familiar with can be particularly useful to allow confident data extraction. Although we ranked the languages by agreement, based on statistical analyses, we do not claim that the exact ranking truly represents the actual level of accuracy one could expect from future data extractions of translated articles. However, it may be fair to say that one can expect fair to good translation (for the purposes of data extraction) from European languages, fair translation from Japanese and Korean; but often poor translation from Chinese and Hebrew.

Before the systematic review community can be confident in the value of using Google Translate to allow inclusion of non-English language articles, more research is needed to explore its value and its limitations. A future evaluation could focus on specific languages and possibly on a narrower or simpler list of data extraction elements. A followup study should also perform double (or more) data extraction for both the original language and the translated articles, or otherwise control for innate differences among extractors; this would allow a better determination that lack of agreement in extraction are due to translation errors, rather than differences among extractors. This investigation focused on Google Translate as a translation tool, but there are other online, free translation programs that should also be tested, and possibly compared. A formal collaborative study by the EPCs could harness the language skills across the different centers, would enable multiple duplication of data extractions, and would improve the generalizability of experiences of extracting translated articles beyond those of a single EPC.

We conclude that more research is necessary to better understand the utility of this new translation tool to reduce the risk of language bias in systematic review. However, in the meantime, it may be worthwhile for EPCs to devote the small amount of resources and effort necessary to try Google Translate to include non-English articles. It will be important, however, to recognize that extraction of these articles is more prone to error than extraction of typical English language articles. Therefore, judgment will be needed to determine how much confidence the reviewers have in the accuracy of the data extraction of these articles, and to recognize that apparently missing data or unclearly reported data may be more a factor of poor translation than of poor methodology. Investigating Google Translate (or other Web-based translation tools) as a collaborative research project across all EPCs would take advantage of the quick accrual rate of a multicenter study as well as the benefits of a prospective study design. It would allow for coordination of the various centers’ experiences with using translated articles in reports and will reduce the anecdotal nature of a single EPC’s experiment.