# Examples of Poorly Translated Articles

This appendix includes examples of difficult to interpret, incomplete, mangled, or otherwise difficult translations. The translations are organized by language. The appendix contains only de-identified fragments.

## Chinese

“Gao oxaliplatin (GO)”

“advanced NSCLC 51 [image] ”

“party is ginseng, astragalus, stabbed five tomato, cantharidin, the main components of ginseng saponin, astragalus saponin, thorn Five tomato polysaccharide to a cantharidin,”

“1.4.2 KPS score of [2], after treatment than before treatment score ≥ 10 points were added to improve, increase or decrease <10 points for the stability, reduce by ≥ 10 points for the decline.”

Figure 1 Untranslated x-axis legend from a Chinese article

Figure 1. Untranslated x-axis legend from a Chinese article.

“Evaluate the purpose of carbon dioxide, $ [F”% colonoscopy is the safety and effectiveness of “Methods to% & $ # patients were randomly divided into [F” Group $ $ j6] &% $ $, and air group j6] 5%! were injected”

“HI Materials and Methods

6 / 6! Study

The “# #] years $ month” to “# #] # 6 in the period from 66 months in the”

“By ZUZZ6% / # statistical package was used for statistical analysis”

“!; A,, anesthesia

Patients were tested before surgery A $, 17: intramuscular injection of atropine $; #, 13, and stability! $, 13 # into the operating room after the d! - “or d”-A line of epidural space puncture”

## French

“SUMMARY

(ETFE study under fGnlt of Eshi Ii Randomized double-blind study plan AOLS, deyait yirfler a sl miclklllMllf honaiopathique, Anka Montana ..... eu Ie sigli6cativement time scignement (SllIIpIate II) and its effects dialre sw diffirents Hngulne coagulation tests. ........ II was that prodllt Inll .. on various parameters of coagulation Ia Hngulne among yolontalres ss GIl cows minutes Sliva ... Sin administration.”

“Thirty minutes after taking the second dose tube, the technician again efTectuait bleeding time and collect tubes of blood.”

Figure 2 A table with untranslated text (“sujet”, “periode”, “moyenne”) from a French article

Figure 2. A table with untranslated text (“sujet”, “periode”, “moyenne”) from a French article.

[Added by Research Assistant:

Groupe = group

Moyenne = average

Periode = period

* T: Time of initial bleeding

** T3: Bleeding time 30 minutes after treatment

*** Y, and Y2: T3-To]

“Acknowledgements This study ae subsidized by the Fonds de la recherche en santé du Québec.”

“Mari6 (%)”

“C-1, DL (mmol / L)”

“| *. gloomy subjects in each group.”

Figure 3 Translated text where columns of text overlap heavily so that large portions of the text are unreadable

Figure 3. Translated text where columns of text overlap heavily so that large portions of the text are unreadable.

## German

“The “guided Trepansystem” after Krumeich (GTS) is now widely used.”

“often associated with a Transplantateinschmelzung or ideal”

Figure 4 Table with both failure to translate German text and translation into unintelligible English (e.g., “Fadenruptur first or 2 run away, the thread”)

Figure 4. Table with both failure to translate German text and translation into unintelligible English (e.g., “Fadenruptur first or 2 run away, the thread”).

“compliance [4] and a higher Suizidrisiko [5]. This is all the more weight to”

Figure 5 Both overlapping English text and unintelligble English (e.g., the lenses Tues cke te show a locally)

Figure 5. Both overlapping English text and unintelligble English (e.g., the lenses Tues cke te show a locally).

## Hebrew

“Following:

- Set a psychiatric diagnosis); Likelihood ratio = 58.1”

“.) OR = 1.6, 95% CI = 1.01 to 2.5 (“

Figure 6 Untranslated Hebrew in column headers within a table

Figure 6. Untranslated Hebrew in column headers within a table.

“Subjects Tanvahtiym. Subjects with Ednge”that my position had fewer sleep breathing disorders”

“Subjects were not Tanvahtiym many breathing disorders are followed Sacheveat back and after Sacheveat Party, for continuous positive airway pressure (CPAP (“

“Table 2 also concentrated nocturnal Polisumanugerfeim data subjects’ Suffering Bdnge”

“This work demonstrated that% 53.8 of 2077 patients”

“the criteria K to N. Y. Y. Y. Y. F from a D from S. F. J. R. C. K. S. J. and S. Y. D and C to D to Y. A’s in H and N D to K and Z to A.”

Figure 7 Untranslated Hebrew in a column of data within a table (rows 13 to 16)

Figure 7. Untranslated Hebrew in a column of data within a table (rows 13 to 16).

[Research Assistant added:

13 Rafapne
14 Muxipne
15 At what age) in (do you think the more likely it is pharyngitis Straftokoakit?
- 16.14-3]

## Italian

Figure 8 Italian text with Google translate balloon: “Contribute a better translation.”

Figure 8. Italian text with Google translate balloon: “Contribute a better translation.”

Figure 9 Translated text where columns of text overlap heavily so that large portions of the text are unreadable

Figure 9. Translated text where columns of text overlap heavily so that large portions of the text are unreadable.

## Japanese

“➇ The laboratory values of WBC ≧ 3,000 / Mm3, i ≧ platelets Number 10xlO4/mm3, 6 ≧ total protein.Og / dL (A / G ≧ 1.0), AST, ALT 100 ≦, ≦ serum creatinine 1.5 mg / d Shino patients meet the criteria.

Registration of cases, after the eligibility check at the Central Registration System to the intestines or rectum before forming another layer, were provisionally registered. Submitted 10 months after surgery - 12 “10 months a progress report on the treatment” to exclude based on the following cases, the remaining cases were registered for this.”

“total dose prescribed period of 80 or more ➄% doing therapy.”

“1. Target

[image] period from March 1997 until August 1996”

“6. See observation day and observe

1) Sun observation

Hazime Higai administration was required to observe the day and 4 weeks after 2 weeks.”

“8. Stop loss criteria”

Figure 10 Translated text where columns of text overlap heavily so that large portions of the text are unreadable

Figure 10. Translated text where columns of text overlap heavily so that large portions of the text are unreadable.

Research Assistant’s table:

Medication status in Table 3

Actual duration of treatment | Treated group 1 year | Three treatment groups in
| (n=108) | (n=113)
Less than 10 months
10 to 12 months

Which had to be matched with:

Figure 11 Untranslated Japanese within a table

Figure 11. Untranslated Japanese within a table.

## Korean

“four with a flexible over-tube was yongha.”

“proximal wibunmunbueseo”

“The number of patients the PPI group, 25 patients were 22 patients in the control group this average age of four the two groups, there was no significant difference in gender ratio.”

“High kicks

Last EVL for acute bleeding caused by…”

“2. Endoscopy chiyuyul”

“cure rates for my PD ransopeurajol 30 mg 75–93%, rabepeurajol 20 mg 76–92%”

## Portuguese

“There may perfuração”

“Between 20% and 40% of patients with grade II and III lesions will develop estenose”

Figure 12 Portion of a translated table with overlapping text and poor spacing of various words making the meaning unintelligible

Figure 12. Portion of a translated table with overlapping text and poor spacing of various words making the meaning unintelligible.

## Spanish

Figure 13 Overlapping text

Figure 13. Overlapping text.