# List of Articles Translated and Included

## Chinese

Hu XY, Zhou YX, Xu SZ, et al. Effects of probiotics on feeding intolerance in low birth weight premature infants. [Chinese]. Zhongguo Dangdai Erke Zazhi. 2010;12(9):693-5. [pmid: 20849715].
Li H, Dong L, Li Y, et al. A randomized clinical trial of combination of Aidi injection with Gemcitabine and Oxaliplatin regimen or Go regimen only in the treatment of advanced non-small-cell lung cancer. [Chinese]. Chinese Journal of Lung Cancer. 2008;11(4):570-3. [pmid: 20735973].
Liu X, Liu D, Li J, et al. Safety and efficacy of carbon dioxide insufflation during colonoscopy. [Chinese]. Zhong Nan da Xue Xue Bao. 2009;Yi(8):825-9. [pmid: 19734597].
Tang FZ, Liu YL, Wen FQ, et al. Comparison of therapeutic effects in severe nocturia: gradual versus immediate drug withdrawal. [Chinese]. Zhongguo Dangdai Erke Zazhi. 2010;12(3):198-200. [pmid: 20350430].
Wang P, Yang J, Liu G, et al. Effects of moxibustion at head-points on levels of somatostatin and arginine vasopressin from cerebrospinal fluid in patients with vascular dementia: a randomized controlled trial. [Chinese]. Zhong Xi Yi Jie He Xue Bao. Journal of Chinese Integrative Medicine. 2010;8(7):636-40. [pmid: 20619139].
Xu JS, Yang JW, Gu MN, et al. Effects of fentanyl on EC50 of ropivacaine for postoperative epidural analgesia after gynecological surgery. [Chinese]. Di Yi Junyi Daxue Xuebao. 2004;24(11):1326-7. [pmid: 15567796].
Xu XH, Chang YT, Li L, et al. Effect of fructose-1,6-diphosphete on myocardial preservation during pulmonary operations. [Chinese]. Zhong Nan da Xue Xue Bao. 2008;Yi(10):966-9. [pmid: 19001742].
Yang MH, Li M, Dou YQ, et al. Effects of Bushen Huoxue Granule on motor function in patients with Parkinson’s disease: a multicenter, randomized, double-blind and placebo-controlled trial. [Chinese]. Zhong Xi Yi Jie He Xue Bao. Journal of Chinese Integrative Medicine. 2010;8(3):231-7. [pmid: 20226144].
Yi JH, Li RR. Influence of near-work and outdoor activities on myopia progression in school children. [Chinese]. Zhongguo Dangdai Erke Zazhi. 2011;13(1):32-5. [pmid: 21251384].
Zhang GQ, Ge L, Ding W, et al. The value of portal vein chemotherapy after radical resection in delaying intrahepatic recurrence of stage II primary hepatocellular carcinoma. [Chinese]. Aizheng. 2008;27(12):1297-301. [pmid: 19079997].

## French

Aubin M, Vezina L, Maziade J, et al. Control of arterial hypertension: effectiveness of an intervention performed by family practitioners. [French]. Canadian Family Physician. 1994;40:1742-52. [pmid: 7950469].
Aydin A, Karadayi K, Aykan U, et al. Effectiveness of topical ciclosporin A treatment after excision of primary pterygium and limbal conjunctival autograft. [French][Erratum appears in J Fr Ophtalmol. 2010 Jun;33(6):435]. Journal Francais d Opthalmologie. 2008;31(7):699-704.
Baillargeon L, Drouin J, Desjardins L, et al. The effects of Arnica Montana on blood coagulation. Randomized controlled trial. [French][Erratum appears in Can Fam Physician 1994 Feb;40:225]. Canadian Family Physician. 1993;39:2362-7. [pmid: 7903572].
Devogelaere T, Beresniak A, Raymaeckers A, et al. Clinical study of Supranettes pads in the treatment of seasonal or perennial allergic conjunctivitis in children. [French]. Journal Francais d Opthalmologie. 2006;29(6):593-8.
Fekih M, Ben ZN, Jnifen A, et al. Comparing two Prepidil gel regimens for cervical ripening before induction of labor at term: a randomized trial. [French]. Journal de Gynecologie, Obstetrique et Biologie de la Reproduction. 2009;38(4):335-40.
Gadioux-Madern F, Lelez ML, Sellami L, et al. Influence of the instillation of two versus three eyedrops of cyclopentolate 0.5% on refraction of Caucasian nonstrabismic children. [French]. Journal Francais d Opthalmologie. 2008;31(1):51-5.
Gosselin P, Verreault R, Gaudreault C, et al. Dietary treatment of mild to moderate hypercholesterolemia. Effectiveness of different interventions. [French]. Canadian Family Physician. 1996;42:2160-7. [pmid: 8974552].
Lamouliatte H, Perie F, Joubert-Collin M. Treatment of Helicobacter pylori infection with lansoprazole 30 mg or 60 mg combined with two antibiotics for duodenal ulcers. [French]. Gastroenterologie Clinique et Biologique. 2000;24(5):495-500. [pmid: 10891736].
Polonovski JM, El MM. Treatment of acute maxillary sinusitis in adults. Comparison of cefpodoxime-proxetil and amoxicillin-clavulanic acid. [French]. Presse Medicale. 2006;35(1:Pt 1):t-8.
Rolachon A, Kezachian G, Causse X, et al. Value of high-dose interferon-alpha in chronic viral hepatitis C patients non-responder to a 1st treatment. Pilot study prospective and randomized trial. [French]. Gastroenterologie Clinique et Biologique. 1997;21(12):924-8. [pmid: 9587555].

## German

Bechdolf A, Pholmann B, Guttgemanns J, et al. Motivationsbehandlung für Patienten mit der Doppeldiagnose Psychose und Sucht Ergebnisse einer randomisierten Studie. Nervenarzt. 2011. Epub ahead of print.
Birnbaum F, Schwartzkopff J, Bohringer D, et al. Penetrating keratoplasty with intrastromal corneal ring. A prospective randomized study. [German]. Ophthalmologe. 2008;105(5):452-6. [pmid: 17899113].
Borner M, Burkle H, Trojan S, et al. Intra-articular ketamine after arthroscopic knee surgery. Optimisation of postoperative analgesia. [German]. Anaesthesist. 2007;56(11):1120-7. [pmid: 17726586].
Langer C, Forster H, Konietschke F, et al. Mesh shrinkage in hernia surgery: data from a prospective randomized double-blinded clinical study. [German]. Chirurg. 2010;81(8):735-42. [pmid: 20186380].
Marx S, Cimniak U, Beckert R, et al. Chronic prostatitis/chronic pelvic pain syndrome. Influence of osteopathic treatment - a randomized controlled study. [German]. Urologe. Ausg. 2009;(11):1339-45. [pmid: 19705093].
Meybohm P, Hanss R, Bein B, et al. Comparison of premedication regimes. A randomized, controlled trial. [German]. Anaesthesist. 2007;56(9):890-2. [pmid: 17551699].
Schnabel M, Vassiliou T, Schmidt T, et al. Results of early mobilisation of acute whiplash injuries. [German]. Der Schmerz. 2002;16(1):15-21. [pmid: 11845337].
Stoffels I, Wolter TP, Sailer AM, et al. The impact of silicone spray on scar formation. A single-center placebo-controlled double-blind trial. [German]. Hautarzt. 2010;61(4):332-8. [pmid: 19967328].
Warlo I, Krummenauer F, Dick HB. Rotational stability in intraocular lenses with C-loop haptics versus Z haptics in cataract surgery. A prospective randomised comparison. [German]. Ophthalmologe. 2005;102(10):987-92. [pmid: 15785909].
Wohlrab D, Droege JW, Mendel T, et al. Minimally invasive vs. transgluteal total hip replacement. A 3-month follow-up of a prospective randomized clinical study. [German]. Orthopade. 2008;37(11):1121-6. [pmid: 18810386].

## Hebrew

Gimelfarb Y, Natan Z. Risk factors for suicide attempts in dual diagnosis patients. [Hebrew]. Harefuah. 2009;148(6):355-8. [pmid: 19902596].
Haimov I, Vadas L. Sleep in older adults: association between chronic insomnia and cognitive functioning. [Hebrew]. Harefuah. 2009;148(5):310-4. [pmid: 19630361].
Kugelman A, Anabussi S, Sharon N, et al. The association between pertussis during infancy and childhood asthma. [Hebrew]. Harefuah. 2009;148(2):80-3. [pmid: 19627033].
Oksenberg A, Arons E, Greenberg-Dotan S, et al. The significance of body posture on breathing abnormalities during sleep: data analysis of 2077 obstructive sleep apnea patients. [Hebrew]. Harefuah. 2009;148(5):304-9. [pmid: 19630360].
Oliven A, Tov N, Odeh M, et al. Electrical stimulation of the genioglossus to improve pharyngeal patency in obstructive sleep apnea: comparison of results obtained during sleep and anesthesia. [Hebrew]. Harefuah. 2009;148(5):315-9. [pmid: 19630362].
Otto O, Peleg R, Press Y. Streptococcal pharyngitis among children: comparison of attitudes between family physicians and pediatricians. [Hebrew]. Harefuah. 2009;148(8):511-4. [pmid: 19899252].
Perlitz Y, Gtezer-Soltzman S, Peleg A, et al. Correlation of maternal serum and amniotic fluid leptin and insulin levels with neonatal birth weight. [Hebrew]. Harefuah. 2009;148(7):420-3. [pmid: 19848325].
Rosenberg E, Elkrinawi S, Goldbart A, et al. Obstructive sleep apnea syndrome in young infants. [Hebrew]. Harefuah. 2009;148(5):295-9. [pmid: 19630358].

## Italian

Berti M, Danelli G, Antonino FA, et al. 0.2% ropivacaine with or without sufentanil for patient-controlled epidural analgesia after anterior cruciate ligament repair. Minerva Anestesiologica. 2005;71(3):93-100. [pmid: 15714185].
Borghi B, Laici C, Iuorio S, et al. Epidural vs general anaesthesia. [Italian]. Minerva Anestesiologica. 2002;68(4):171-7. [pmid: 12024077].
Brizzi A, Greco F, Malvasi A, et al. Comparison of sequential combined spinal-epidural anesthesia and spinal anesthesia for cesarean section. Minerva Anestesiologica. 2005;71(11):701-9. [pmid: 16278629].
Catania S, Gallo A. Clinical efficacy and tolerability of short course therapy with cefaclor compared with long-term therapy for treatment of acute otitis media in children. [Italian]. Infezioni in Medicina. 2004;12(4):259-65. [pmid: 15729016].
Chisari G, Sanfilippo M, Reibaldi M. Treatment of bacterial conjuntivitis with topical ciprofloxacin and norfloxacin: a comparative study. [Italian]. Infezioni in Medicina. 2003;11(1):25-30. [pmid: 12719667].
Cuomo G, Molinaro G, La MG, et al. A comparison between the Simplified Disease Activity Index (SDAI) and the Disease Activity Score (DAS28) as measure of response to treatment in patients undergoing different therapeutic regimens. [Italian]. Reumatismo. 2006;58(1):22-5. [pmid: 16639484].
Guarda Nardini L, Oliviero F, Ramonda R, et al. Influence of intra-articular injections of sodium hyaluronate on clinical features and synovial fluid nitric oxide levels of temporomandibular osteoarthritis. [Italian]. Reumatismo. 2004;56(4):272-7. [pmid: 15643481].
Lo Martire N, Savastano S, Rossini L, et al. Topical anesthesia for cataract surgery with phacoemulsification: lidocaine 2% vs ropivacaine 1%Preliminary results. [Italian]. Minerva Anestesiologica. 2002;68(6):529-35. [pmid: 12105409].
Nieddu ME, Menza L, Baldi F, et al. Efficacy of Cellfood’s therapy (deutrosulfazyme) in fibromyalgia. [Italian]. Reumatismo. 2007;59(4):316-21. [pmid: 18157288].
Pasero GP, Di MO. Analgesic dose range finding of lornoxicam compared to diclofenac. Crossover double blind study in rheumatoid arthritis. [Italian]. Reumatismo. 2002;54(3):238-42. [pmid: 12404032].

## Japanese

Adachi Y, Sumikuma T, Kagami R, et al. Improvement of patient adherence by mixing oral itraconazole solution with a beverage (orange juice). [Japanese]. Rinsho Ketsueki. Japanese Journal of Clinical Hematology. 2010;51(5):315-9. [pmid: 20534951].
Hirata K, Nakahara S, Shimokobe T, et al. A randomized controlled trial of postoperative adjuvant chemotherapy for colorectal cancer-optimal duration of the treatment. [Japanese]. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2009;36(1):77-82. [pmid: 19151567].
Kurokawa M, Masuda Y, Noda M, et al. Minimal effective dose on serum cholesterol concentration and the safety evaluation of dressing containing plant sterol in Japanese subjects. [Japanese]. Journal of Oleo Science. 2008;57(1):23-33. [pmid: 18075220].
Miura H, Takahashi Y, Kitabatake Y. Influence of group training on pulse wave velocity in elderly women. [Japanese]. Nippon Koshu Eisei Zasshi. Japanese Journal of Public Health. 2010;57(4):271-8. [pmid: 20560409].
Mochizuki M, Hatsugaya M, Rokujoh E, et al. Randomized controlled study on the effectiveness of community pharmacists’ advice for smoking cessation by Nicorette--evaluation at three months after initiation. [Japanese]. Yakugaku Zasshi. Journal of the Pharmaceutical Society of Japan. 2004;124(12):989-95. [pmid: 15577269].
Satou Y, Kanda J, Okumura M, et al. An analysis of the educational effects of group counseling with visual aids: efforts to prevent diabetes in a business office setting. [Japanese]. Sangyo Eiseigaku Zasshi. 2004;46(4):117-21. [pmid: 15382712].
Sawada A, Sakata N, Higuchi B, et al. Comparison of micafungin and fosfluconazole as prophylaxis for invasive fungal infection during neutropenia in children undergoing chemotherapy and hematopoietic stem cell transplantation. [Japanese]. Rinsho Ketsueki. Japanese Journal of Clinical Hematology. 2009;50(12):1692-9. [pmid: 20068276].
Sekine Y, Takai Y, Nishii O, et al. Establishment of an optimum bowel preparation method before gynecologic laparoscopic surgery. [Japanese]. Yakugaku Zasshi. Journal of the Pharmaceutical Society of Japan. 2001;121(8):637-45. [pmid: 11523124].
Sugiura M, Hata Y, Fukuda T, et al. One-week application of terbinafine cream compared with four-week application in treatment of Tinea pedis. [Japanese]. Japanese Journal of Medical Mycology. 2001;42(4):223-8. [pmid: 11704752].
Takahashi M, Araki A, Ito H. Development of a new method for simple dietary education in elderly individuals with diabetes mellitus. [Japanese]. Nippon Ronen Igakkai Zasshi. Japanese Journal of Geriatrics. 2002;39(5):527-32. [pmid: 12404749].

## Korean

Boo GB, Oh JC, Lee BJ, et al. The effect of proton pump inhibitor on healing of post-esophageal variceal ligation ulcers. [Korean]. Korean Journal of Gastroenterology. Taehan Sohwagi Hakhoe Chi. 2008;51(4):232-40. [pmid: 18516002].
Cho SB, Park KJ, Lee JS, et al. Comparison of terlipressin and octreotide with variceal ligation for controlling acute esophageal variceal bleeding--a randomized prospective study. [Korean]. Korean Journal of Hepatology. 2006;12(3):385-93. [pmid: 16998290].
Choi WH, Park DI, Oh SJ, et al. Effectiveness of 10 day-sequential therapy for Helicobacter pylori eradication in Korea. [Korean]. Korean Journal of Gastroenterology. Taehan Sohwagi Hakhoe Chi. 2008;51(5):280-4. [pmid: 18516011].
Gwak JH, Kim JY, Kim HJ, et al. The Effect of Isoflavone and Gamma-linolenic Acid Supplementation on Serum Lipids and Menopausal Symptoms in Postmenopausal Women. [Korean]. Korean J Nutr. 2010;43(2):123-31.
Jeong HY, Lee BS, Sung JK, et al. A randomized, prospective, comparative, multicenter study of rabeprazole and ranitidine in the treatment of reflux esophagitis. [Korean]. Korean Journal of Gastroenterology. Taehan Sohwagi Hakhoe Chi. 2006;47(1):15-21. [pmid: 16434864].
Kim JS, Kim HJ, Woo YH, et al. Effects on changes in femoral vein blood flow velocity with the use of lower extremity compression for critical patients with brain injury. [Korean]. Journal of Korean Academy of Nursing. 2009;39(2):288-97. [pmid: 19411800].
Kim YG, Moon JT, Lee KM, et al. The effects of probiotics on symptoms of irritable bowel syndrome. [Korean]. Korean Journal of Gastroenterology. Taehan Sohwagi Hakhoe Chi. 2006;47(6):413-9. [pmid: 16809947].
Lee SS, Yoon H. A comparison of the effect of lidocaine or sodium bicarbonate mixed with rocuronium on withdrawal movement, mean arterial pressure and heart rate during rocuronium injection. [Korean]. Journal of Korean Academy of Nursing. 2009;39(2):270-8. [pmid: 19411798].
Park JY, Kim JY, Lee SP, et al. The Effect of Green Coffee Bean Extract Supplementation on Body Fat Reduction in Overweight/Obese Women. [Korean]. Korean J Nutr. 2010;43(4):374-81.
Seo YJ, Yoon H. The effects of preemptive analgesia of morphine and ketorolac on postoperative pain, cortisol, O(2) saturation and heart rate. [Korean]. Journal of Korean Academy of Nursing. 2008;38(5):720-9. [pmid: 19114761].

## Portuguese

Amorim MM, Lippo LA, Costa AA, et al. Transdermal nitroglycerin versus oral nifedipine administration for tocolysis: a randomized clinical trial. [Portuguese]. Revista Brasileira de Ginecologia e Obstetricia. 2009;31(11):552-8. [pmid: 20084326].
Camargo MA, Lopes LR, Grangeia TA, et al. Use of corticosteroids after esophageal dilations on patients with corrosive stenosis: prospective, randomized and double-blind study. [Portuguese]. Revista Da Associacao Medica Brasileira. 2003;49(3):286-92. [pmid: 14666354].
Carramao S, Auge AP, Pacetta AM, et al. A randomized comparison of two vaginal procedures for the treatment of uterine prolapse using polypropylene mesh: hysteropexy versus hysterectomy. [Portuguese]. Revista do Colegio Brasileiro de Cirurgioes. 2009;36(1):65-72. [pmid: 20076870].
de Arruda LH, Kodani V, Bastos FA, et al. A prospective, randomized, open and comparative study to evaluate the safety and efficacy of blue light treatment versus a topical benzoyl peroxide 5% formulation in patients with acne grade II and III. [Portuguese]. Anais Brasileiros de Dermatologia. 2009;84(5):463-8. [pmid: 20098847].
Machado AF, Pedreira ML, Chaud MN. Prospective, randomized and controlled trial on the dwell time of peripheral intravenous catheters in children, according to three dressing regimens. [Portuguese]. Revista Latino-Americana de Enfermagem. 2005;13(3):291-8. [pmid: 16059533].
Magacho L, Reis R, Pigini MA, et al. 2% ibopamine vs. water-drinking test as a provocative test for glaucoma. [Portuguese]. Arquivos Brasileiros de Oftalmologia. 2008;71(4):499-503. [pmid: 18797657].
Muller KR, Bonamigo RR, Crestani TA, et al. Evaluation of patients’ learning about the ABCD rule: A randomized study in southern Brazil. [Portuguese]. Anais Brasileiros de Dermatologia. 2009;84(6):593-8. [pmid: 20191170].
Pereira PP, Oliveira AL, Cabar FR, et al. Comparative study of manual vacuum aspiration and uterine curettage for treatment of abortion. [Portuguese]. Revista Da Associacao Medica Brasileira. 2006;52(5):304-7. [pmid: 17160302].
Santos FM, Rodrigues RG, Trindade-Filho EM. Physical exercise versus exercise program using electrical stimulation devices for home use. [Portuguese]. Revista de Saude Publica. 2008;42(1):117-22. [pmid: 18200348].
Simao AN, Godeny P, Lozovoy MA, et al. Effect of n-3 fatty acids in glycemic and lipid profiles, oxidative stress and total antioxidant capacity in patients with the metabolic syndrome. [Portuguese]. Arquivos Brasileiros de Endocrinologia e Metabologia. 2010;54(5):463-9. [pmid: 20694407].

## Spanish

Bonetto G, Salvatico E, Varela N, et al. Pain prevention in term neonates: randomized trial for three methods. [Spanish]. Archivos Argentinos de Pediatria. 2008;106(5):392-6. [pmid: 19030637].
Ceriani Cernadas JM, Carroli G, Pellegrini L, et al. The effect of early and delayed umbilical cord clamping on ferritin levels in term infants at six months of life: a randomized, controlled trial. [Spanish]. Archivos Argentinos de Pediatria. 2010;108(3):201-8. [pmid: 20544134].
de Luis DA, de la FB, Izaola O, et al. Randomized clinical trial with a inulin enriched cookie on risk cardiovascular factor in obese patients. [Spanish]. Nutricion Hospitalaria. 2010;25(1):53-9. [pmid: 20204256].
Garcia-Talavera Espin NV, Gomez Sanchez MB, Zomeno Ros AI, et al. Comparative study of two enteral feeding formulas in hospitalized elders: casein versus soybean protein. [Spanish]. Nutricion Hospitalaria. 2010;25(4):606-12. [pmid: 20694297].
Gomez-Garcia A, Hernandez-Salazar E, Gonzalez-Ortiz M, et al. Effect of oral zinc administration on insulin sensitivity, leptin and androgens in obese males. [Spanish]. Revista Medica de Chile. 2006;134(3):279-84. [pmid: 16676098].
Lopez-De-Blanc SA, Salati-De-Mugnolo N, Femopase FL, et al. Antifungal topical therapy in oral chronic candidosis. A comparative study. Medicina Oral. 2002;7(4):260-70. [pmid: 12134127].
Martinez Gonzalez JM, Benito PB, Fernandez CF, et al. A comparative study of direct mandibular nerve block and the Akinosi technique. Medicina Oral. 2003;8(2):143-9. [pmid: 12618675].
Perez-Barcena J, Barcelo B, Homar J, et al. Comparison of the effectiveness of pentobarbital and thiopental in patients with refractory intracranial hypertension. Preliminary report of 20 patients. [Spanish]. Neurocirugia (Asturias, Spain). 2005;16(1):5-12.
Rodriguez Martin C, Castano Sanchez C, Garcia Ortiz L, et al. Efficacy of an educational intervention group on changes in lifestyles in hypertensive patients in primary care: a randomized clinical trial. [Spanish]. Revista Espanola de Salud Publica. 2009;83(3):441-52. [pmid: 19701575].
Vasquez AM, Sanin F, Alvarez LG, et al. Therapeutic efficacy of a regimen of artesunate-mefloquine-primaquine treatment for Plasmodium falciparum malaria and treatment effects on gametocytic development. [Spanish]. Biomedica. 2009;29(2):307-19. [pmid: 20128355].

## English

Artinian NT, Flack JM, Nordstrom CK, et al. Effects of nurse-managed telemonitoring on blood pressure at 12-month follow-up among urban African Americans. Nurs Res. 2007;56(5):312-22. [pmid: 17846552].
Binanay C, Califf RM, Hasselblad V, et al. Evaluation study of congestive heart failure and pulmonary artery catheterization effectiveness: the ESCAPE trial. JAMA. 2005;294(13):1625-33. [pmid: 16204662].
Bjorkman M, Sorva A, Risteli J, et al. Vitamin D supplementation has minor effects on parathyroid hormone and bone turnover markers in vitamin D-deficient bedridden older patients. Age Ageing. 2008;37(1):25-31. [pmid: 17965037].
Calo L, Lamberti F, Loricchio ML, et al. Left atrial ablation versus biatrial ablation for persistent and permanent atrial fibrillation: a prospective and randomized study. J Am Coll Cardiol. 2006;47(12):2504-12. [pmid: 16781381].
Domagk D, Menzel J, Seidel M, et al. Endoluminal gastroplasty (EndoCinch) versus endoscopic polymer implantation (Enteryx) for treatment of gastroesophageal reflux disease: 6-month results of a prospective, randomized trial. Am J Gastroenterol. 2006;101(3):422-30. [pmid: 16542275].
Gagnadoux F, Fleury B, Vielle B, et al. Titrated mandibular advancement versus positive airway pressure for sleep apnoea. Eur Respir J. 2009;34(4):914-20. [pmid: 19324954].
Meador K, Loring D, Nichols M, et al. Preliminary findings of high-dose thiamine in dementia of Alzheimer’s type. J Geriatr Psychiatry Neurol. 1993;6(4):222-9. [pmid: 8251051].
Noel-Weiss J, Rupp A, Cragg B, et al. Randomized controlled trial to determine effects of prenatal breastfeeding workshop on maternal breastfeeding self-efficacy and breastfeeding duration. J Obstet Gynecol Neonatal Nurs. 2006;35(5):616-24.
Schiele F, Meneveau N, Vuillemenot A, et al. Impact of intravascular ultrasound guidance in stent deployment on 6-month restenosis rate: a multicenter, randomized study comparing two strategies--with and without intravascular ultrasound guidance. RESIST Study Group. REStenosis after Ivus guided STenting. J Am Coll Cardiol. 1998;32(2):320-8. [pmid: 9708456].
Webster J, Marshall F, Abdalla M, et al. Randomised comparison of percutaneous angioplasty vs continued medical therapy for hypertensive patients with atheromatous renal artery stenosis. Scottish and Newcastle Renal Artery Stenosis Collaborative Group. J Hum Hypertens. 1998;12(5):329-35. [pmid: 9655655].