# Appendixes

Appendix A Annotated Data Extraction Forms

Appendix B List of Articles Translated and Included

Appendix C Examples of Poorly Translated Articles