# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
EPC: Evidence-based Practice Center
IOM: Institute of Medicine
IQR: interquartile range
OCR: optical character recognition
RCT: randomized controlled trial