# Results

Table 2 provides the results of the outreach.

Table 2 Transparency of reporting: summary of results of outreach to study investigators

Author | Available on clinicaltrials.gov | Available on other registries | Outcomes available on registry | Barriers to registering study | Barriers to presenting information on critical components on registries | Availability of materials for replication | Critical components for replication as identified by study authors
Beidas et al., 2012^5^ | No | No | NA | Not a traditional clinical trial in that it focused on changing clinician behavior and did not enroll patients; therefore did not attempt to include it on the clinical trials registry. | NA | In existing publications on the trial | Augmented training: focus on principles of treatment and use of experiential learning; the ongoing support and consultation
Bickman et al., 2011^16^ | Yes | No | No | None | Not perceived as necessary because author did not experience barriers in dissemination through routine outlets such as publications and presentations | NA | Feedback
Carroll et al., 2013^6^ | Yes | NR | Yes | NR | NR | NR | NR
Epstein et al., 2011^7^ | Yes | No | No | clinicaltrials.gov is made for pharmaceutical clinical trials and was very difficult to complete some of the fields for this non-pharmaceutical study. It required an extended call with tech support at clinicaltrials.gov to get results posted correctly. | None but noted no community-based pediatricians has contacted author through clinicaltrials.gov. | NA | 1. an internet based platform through which parents, teachers, and pediatricians all input information about the target child during initial ADHD assessment and treatment, which then resulted in a report; 2. change in office flow
Epstein et al., 2007^8^ | No | No | NA | No barriers noted but the authors did not attempt registration because it was not mandated at the start of the trial | NA | Published materials or contact authors | Recruitment of patients from community-based pediatric practices.
Garner et al., 2012^9^ | Yes | No | No | None given that clinicaltrials.gov automatically indexed publications via the ClinicalTrials.gov Identifier | A study registry could serve as a repository but unclear whether it could be used for this purpose. | None | Financial incentives provided to the staff delivering the intervention
Glisson et al., 2012^10, 11^ | No | No | NA | Did not attempt registration so no barriers noted | NA | Publications, website, intervention training materials | The ARC intervention strategies depend on trained specialists who work at all levels of a service system to: (a) embed guiding principles for improving services, (b) develop shared mental models among organizational members to support the improvement effort, and (c) enact organizational tools (e.g., feedback) for identifying and addressing service barriers.
Glisson et al., 2010^17^ | No | No | NA | Did not attempt registration so no barriers noted | NA | Publications, website, intervention training materials | The ARC intervention strategies depend on trained specialists who work at all levels of a service system to: (a) embed guiding principles for improving services, (b) develop shared mental models among organizational members to support the improvement effort, and (c) enact organizational tools (e.g., feedback) for identifying and addressing service barriers.
Gully et al., 2008^4^ (study 1) | No | NR | NR | NR | NR | NR | NR
Gully et al., 2008^4^ (study 2) | No | NR | NR | NR | NR | NR | NR
Henggeler et al., 2008^12^ | No | NR | NR | NR | NR | NR | NR
Henggeler et al., 2013^13^ | No | NR | NR | NR | NR | NR | NR
Lester et al., 2009^14^ | No | NR | NR | NR | NR | NR | NR
Lochman et al., 2009^15^ | No | No | NA | Did not attempt registration so no barriers noted | NA | Contact authors | Audit and feedback components where trainers reviewed the rate of completion of session objectives and provided individualized supervisory feedback
Ronsely et al., 2012^19^ | No | NR | NR | NR | NR | NR | NR
Sterling et al., 2015 ^20^ | No | No | NA | No barriers noted but the authors did not attempt registration because it was not mandated | A registry could be of use if it included very specific protocols to assist people in replicating procedures, either for other studies or for implementation in program settings | NA | Brief training in how to deliver SBIRT in the pediatrician-only arm; embedding a BHCP in the BHCP arm
Wildman et al., 2012^18^ | No | NA | NA | NA | NA | Contact authors | Creating easy referral procedures for primary care providers to use for behavioral health care.

Abbreviations: NA = not applicable; NR = not reported

## Proportion of Studies Reported in Clinicaltrials.gov (KQ 1)

We identified 17 studies, reported in 17 articles^4-19^ (including two studies in a single article,^4^ and one study reported in two articles.^10, 11^ Of these, ten are cRCTs,^6-11, 13-16, 20^ three are parallel-group^4, 5^ or two-stage trials,^17^ and the remaining four are nonrandomized studies.^4, 12, 18, 19^ Only 4—all cRCTS^6, 7, 9, 16^—of the 13 trials appeared in a trials registry (clinicaltrials.gov). All other studies (9 trials^4, 5, 8, 10, 11, 13-15, 17, 20^ and 4 nonrandomized studies^4, 12, 18, 19^) did not appear in a study registry. Additionally, we found three ongoing trials in clinicaltrials.gov that have not yet published results (NCT02097355 (https://clinicaltrials.gov/ct2/show/NCT02097355?term=NCT02097355&rank=1), NCT01829308 (https://clinicaltrials.gov/ct2/show/NCT01829308?term=NCT01829308&rank=1), NCT02271386 (https://clinicaltrials.gov/ct2/show/NCT02271386?term=NCT02271386&rank=1)).

## Comparing Data Between Clinicaltrials.gov and Published Sources (KQ2)

Three of four studies that had been registered in clinicaltrials.gov did not report results (NCT01308879 (https://clinicaltrials.gov/ct2/show/NCT01308879?term=bickman&rank=2),^16^ NCT01016704 (https://clinicaltrials.gov/ct2/show/NCT01016704?term=pay+for+performance+garner&rank=1),^9^ and NCT01056016 (https://clinicaltrials.gov/ct2/show/NCT01056016?term=NCT01056016&rank=1)^7^). One study updated the clinicaltrials.gov registry with results after we sent out a query to the authors (NCT01351064 (https://clinicaltrials.gov/ct2/show/results/NCT01351064?term=carroll+decision&recr=Completed&rank=1&sect=X301256%23evnt)^6^). The results did not differ between the publication and the registry, with one exception. In the publication, the authors present an adjusted odds ratio for the use of structured diagnostic assessments, of 8.0 (95% CI, 1.6 to 40.6). In clinicaltrials.gov, the authors provide raw data rather than adjusted results. Using these data, we calculated an unadjusted odds of 6.9 (95 CI%, 2.6 to 18.6).

## Incomplete, Discontinued, or Unpublished Studies (KQ 3)

We reached out to investigators of three ongoing studies (NCT02097355 (https://clinicaltrials.gov/ct2/show/NCT02097355?term=NCT02097355&rank=1), NCT01829308 (https://clinicaltrials.gov/ct2/show/NCT01829308?term=NCT01829308&rank=1), and NCT02271386 (https://clinicaltrials.gov/ct2/show/NCT02271386?term=NCT02271386&rank=1)). Two did not note barriers to registering their trials, but a third noted difficulties arising from the required data entry fields in clinicaltrials.gov, which are not designed for implementation trials.

We found no discontinued or unpublished studies.

## Utility of Trial Registries for Disseminating Information on Study Outcomes and Processes (KQ 4)

As noted in Table 2, three investigators (lead investigators on two studies and one proxy for two studies with a deceased principal investigator) did not respond to our repeated outreach attempts. A fourth respondent refused because of lack of time and a fifth responded to us but was unable to provide us with information because the principal investigator (lead on two studies) was deceased. Of the remaining ten investigators who completed the questionnaires, six did not attempt to register the study on clinicaltrials.gov and therefore noted no barriers. Three of four respondents who registered their study noted no barriers, with one noting that clinicaltrials.gov automatically indexed publications via the ClinicalTrials.gov Identifier. A fourth noted barriers arising from a mismatch between the nature of the trial and the purpose of clinicaltrials.gov, which was designed for pharmaceutical trials. We asked these four respondents about the utility of adding information on critical components to registries. Two expressed doubts about the utility of clinicaltrials.gov for housing such information, and one did not perceive a need for clinicaltrials.gov to house such information.