# Methods

## KQ 1

We updated our searches for SIMHC draft report and then compare the yield with clinicaltrials.gov, using a dual independent review process.

## KQ 2

a. For studies with information in both peer-reviewed literature and clinicaltrials.gov, we extracted and compared the results, using a dual review process, with a second reviewer checking the first abstractions.
b. For studies with differences in reporting by source, we reached out to study authors via email and phone interview, if necessary, to understand the reasons for the differences.

## KQ 3

a. For discontinued studies, we planned to reach out to authors via email to identify reasons for discontinuation.
b. For ongoing incomplete studies, we supplemented information in clinicaltrials.gov with additional information from study authors via email.
c. For completed and unpublished studies, we planned to reach out to authors of discontinued studies via email to identify reasons for lack of publication

## KQ 4

We reached out to authors of included studies on the reasons for use or non-use of clinicaltrials.gov or other archive sites for information on study conduct and processes.

## KQ 5

We integrated the information for KQs 1-4, using data from searches; abstraction from clinicaltrials.gov; and email, personal interviews, and any additional information provided by authors. We planned to update the strength of evidence and conclusion of the SIMHC report, if we found relevant results.

Table 1 provides the questions for email or personal interview. These are general questions, to be tailored for each interviewee. We obtained IRB exemption before conducting email interviews. We planned a minimum of two email and two telephone outreach attempts before categorizing investigators as non-responders.

Table 1 Questions for authors of studies identified for the SIMHC report or through clinicaltrials.gov

The RTI-UNC Evidence-based Center is conducting a systematic review of strategies to improve mental health for children and adolescents. In addition, our funder, the Agency for Healthcare Research and Quality, has requested an additional investigation of the validity and reliability of clinicaltrials.gov as a potential additional source of information on study conduct, processes and results. Your study [xxx, has been included/is eligible for inclusion] in this review. We are reaching out to you to obtain some additional details about the reporting of your study. Thank you for agreeing to answer our questions.
[For authors of included clinical trials included in the report that do not have a clinicaltrials.gov listing, N=8^4, 5, 8, 10, 11, 13-15, 17^]; 1. We were unable to find a listing for your study on clinicaltrials.gov. Is the study listed on clinicaltrials.gov? If yes, what is the listing number?; 2. Is the study listed elsewhere on another clinical trials registry? If yes, where and what is the listing number?; 3. [If the study results are not listed in any clinical trials registry] Did you attempt to list your study in a clinical trials registry? If yes, what barriers did you experience?; 4. Where can other investigators find supplemental information on your study, such as your experiences with implementing the study or your assessment of critical components necessary for dissemination?; 5. In abstracting your study, we noted that study arms differed in their use of [list specific components here, tailored for each study]. Which of these elements (or otherwise that we may be unaware of) do you consider to be the critical component(s) of your intervention, for those wishing to replicate your study?
[For authors of clinical trials included in the report that have a listing in clinicaltrials.gov, with no results reported in clinicaltrials.gov at the time of our outreach, N=5^6, 7, 9, 16, 20^]; 1. What barriers did you experience or anticipate in presenting your results in a clinical trials registry?; 2. If other investigators wish to scale up your strategy, where can they find necessary information, for example, on your experience of study conduct and processes or your assessment of critical components?; 3. What do you consider to be the critical components of your intervention, for those wishing to replicate your study?; 4. [If such information is not available publicly or in clinicaltrials.gov] What barriers did you experience or anticipate in using a clinical trials registry to make such information available publicly?
[For authors of studies included in the report that are NOT clinical trials, N=4^4, 12, 18, 19^]; 1. If other investigators wish to scale up your strategy, where can they find information on your experience of study conduct and processes or your assessment of critical components necessary for dissemination?; 2. In abstracting your study, we noted that study arms differed in their use of [list specific components here, tailored for each study]. Which of these elements (or otherwise that we may be unaware of) do you consider to be the critical component(s) of your intervention, for those wishing to replicate your study?; 3. [If such information is not available publicly] Are you aware of public registries for observational or nonrandomized studies that might be relevant to your effort? If yes, what are these registries?; 4. What barriers did you experience or anticipate in using registries to make information on study conduct and processes available publicly?
[For authors of ongoing incomplete studies identified via clinicaltrials.gov, not included in the SIMHC review, N=3]; 1. We identified your ongoing study through a search of clinicaltrials.gov as potentially meeting our eligibility criteria for inclusion in our SIMHC review. [If clinicaltrials.gov does not provide this information] What is the anticipated date of completion for this study?; 2. We identified your study through a search of clinicaltrials.gov as potentially meeting our eligibility criteria for inclusion in our SIMHC review. Are there plans to publish the findings? If yes, where will you attempt to publish the material? If no, why not?; 3. Is there any addition information or data that you could share with us that is not currently included on clincaltrials.gov for this study? [If relevant]; 4. Your experience of study conduct and processes may be valuable to others attempting a similar strategy. Where can other investigators find such information?; 5. [If relevant] What barriers did you experience or anticipate in using a clinical trials registry to make such information available publicly?

We also constructed questionnaires in three additional categories but did not find studies in these categories (studies with different results reported in clinicaltrials.gov and published results, eligible discontinued studies identified via clinicaltrials.gov, and complete but unpublished studies identified via clinicaltrials.gov)