# Key Questions

Our key questions (KQ) focus on the utility of clinicaltrials.gov for the systematic review. We also explored the additional issues (described above) that are specific to this review, complex interventions and study designs:

1. Which studies were in the EPC report alone, clinicaltrials.gov alone or in both?
2. For completed studies that were in both sources:
  a. What were the differences, if any, in pre-specified outcome measures, statistical plan and size of the study reported, retention, study conduct, and other details of study design in the peer reviewed literature vs. clinicaltrials.gov?
  b. Were results reported in clinicaltrials.gov for any of the studies? If they were, what were the differences, if any, in the results reported in the peer reviewed literature vs. clinicaltrials.gov?
3. For studies in clinicaltrials.gov that were not completed or discontinued:
  a. For the discontinued studies, were there reasons given for discontinuation? If so, what were they?
  b. For studies that are ongoing but not completed, what was the date of initiation of the studies? Are the studies proceeding according to the original schedule or is there information in clinicaltrials.gov indicating a delay in completion? If there is a delay in completion, what is the reason given?
  c. For studies that are completed but not published, what are the reasons for delay in or lack of publication?
4. For included studies with limited or no information on study processes and conduct in clinicaltrials.gov, what, if any, publicly available sources provide or can provide information on implementation processes? What are the constraints to producing and disseminating this information? What is the perceived utility of clinicaltrials.gov as an archive for such information?
5. What is the impact on the conclusions of the EPC report with and without the information from clinicaltrials.gov? What would be the impact on the strength of evidence (including impact of knowledge of outcomes measured in studies but not reported in the peer reviewed literature)?