# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their considerable support, commitment, and contributions: Elise Berliner, Ph.D., our AHRQ Task Order Officer on the supplemental project; Christine Chang, M.D., M.P.H, our AHRQ Task Order Officer on Strategies to Improve Mental Health Care for Children and Adolescents; and Loraine Monroe, publications specialist.