# Discussion

## Impact of Results on EPC Report (KQ 5)

Table 2 lists the critical components of the study, as identified by study authors. As noted previously, a significant constraint in understanding the results of studies of complex interventions is that they frequently involve complex designs and multiple components. Outreach to study investigators can potentially shed light on critical components that are not otherwise identified in the literature. Ideally, this information can be used to cluster and analyze studies in a systematic review to generate insights and effect estimates from the overall body of evidence. Although we were able to update the report with additional information on critical components in the study descriptors table, our efforts did not result in sufficient information to alter the EPC report materially, for a few reasons. First, despite multiple attempts to reach out to investigators, we had a 59 percent completion rate (we received responses for 10 of 17 studies). Second, among those who responded, use of clinicaltrials.gov was very limited. Only one author posted results in clinicaltrials.gov, and those results did not differ substantively from what was otherwise available to us. Third, investigators who responded may have interpreted our questions in varying ways. Fourth, because of the email format of our outreach, we could not ask followup questions.

## Utility of Clinicaltrials.gov for Systems Interventions

The limited utility of clinicaltrials.gov for supplementing information in this report arises from three sources. First, clinicaltrials.gov is not designed or a good fit for the types of complex designs typified by implementation, dissemination or quality improvement studies. Authors who attempt to register studies on their own reported difficulties. Second, authors did not generally report findings on clinicaltrials.gov. Third, authors do not perceive a need for using clinicaltrials.gov to house information vital to the next generation of implementation studies on the critical components of their interventions.

## Next Steps

Implementation, dissemination, and quality improvement studies such as those covered by this systematic review urgently require substantial documentation of design, processes, and outcomes. Current methods of dissemination simply do not provide sufficient detail at the present time to fully understand or synthesize these strategies and replicate them. As research teams splinter or change trajectories, this information is potentially lost forever (as we inferred from our attempts to reach some authors). At the present time, clinicaltrials.gov does not appear to offer a viable solution to house such information for two reasons: first, the site is not designed for implementation studies and second, authors do not perceive that their audience will seek such information from clinicaltrials.gov. The most viable alternative to enhancing transparency of reporting for these strategies appears to be through journal requirements such as TIDieR.^21^ Recent changes to clinicaltrials.gov specifying that eligible clinical trials include an FDA-regulated device product are likely to deter any further reporting of implementation, dissemination, and quality improvement trials, which often do not include such products.^22^

In the short term, enhanced searches of clinicaltrials.gov and outreach to authors appear to offer limited utility for systematic reviews of implementation, dissemination, and quality improvement trials. However, as the main body of our report indicates, we found that studies of related publications (“sibling” studies of the same intervention, or searches of authors of included interventions) can substantially enhance the descriptions and interpretation of studies. These sibling studies are not available, however, for all included studies and cannot serve as comprehensive and universal sources of information. Future systematic reviews of implementation, dissemination, and quality improvement should anticipate using a combination of citation mining of included studies and searches of sibling studies in order to capture all relevant studies.