# Background and Objectives for the Systematic Review

The RTI International–University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) used an ongoing review, Strategies to Improve Mental Health Care for Children and Adolescents (SIMHC), to generate a report on the additional information gained by including data from clinicaltrials.gov. The purpose of the report was to summarize the evidence on strategies to improve mental health for children, through quality improvement (QI) strategies and interventions with proven effectiveness (e.g., evidence-based practices [EBPs]). The rationale for the topic was to understand how to bridge the gap between observed and achievable processes and outcomes, through strategies that target changes in the organization and delivery of mental health services

Conducting a supplemental transparency project on this review afforded an opportunity to explore additional sources of information on the included strategies, which are generally complex, systems-focused, and underreported. To achieve this goal, we explored the differences between information from published and unpublished sources included in the review and clinicaltrial.gov.

In addition to this primary goal, we had three additional goals. First, we wanted to understand the state of reporting and reporting requirements on a topic of increasing importance: quality improvement (QI), implementation, and dissemination. Despite advances in the evidence base about interventions for treating mental health conditions in children, national health outcomes remain suboptimal, in part because of the failure of systems and providers to adopt QI strategies and interventions with proven efficacy. Given the gap between observed and achievable processes and outcomes, the next critical step is the adoption of effective QI strategies and the development of strategies to implement or disseminate effective interventions.^1-3^ These strategies are complex and may include multiple components, caregivers, or systems. Closing the gap requires more information on not just outcomes of these complex interventions: it requires information on study conduct and processes to allow interpretation of results, assessment of their applicability, and enable scale-up. To achieve this goal, we reached out to authors to understand the utility of clinicaltrials.gov and other archives (e.g., the World Health Organization [WHO] International Clinical Trials Registry and NIHReporter) for information on implementation processes.

Second, we wanted to investigate reporting shortcomings for complex study designs, such as cluster randomized controlled trials (cRCTs). cRCTs require advanced analytic methods (hierarchical linear modeling, for example) that account for clustering at each level of recruitment. To date, our investigation has revealed that a substantial proportion of the included studies in the SIMHC review use cRCTs (10 cRCTs of 17^4-20^ included studies). However, the published data on these trials have been woefully inadequate and do always not permit an independent assessment of the effects of the intervention. These inadequacies hinder not only higher order analyses, such as risk of bias assessment, but also basic calculations of effect size and precision because of poor reporting of retention at the multiple levels of recruitment in a cRCT. To achieve this goal, we sought information from clinicaltrials.gov on more design details, and when they were not available, seek to understand the impediments to reporting through outreach to study authors.

Third, we wanted to understand whether impediments to publication for pragmatic trials and systems interventions exist and if so, why. As noted above, we sought to understand the impediments to publication through outreach to study authors.