# References

1 Agency for Healthcare Research and Quality. Evidence-based Practice Centers. Available at: http://wwwahrqgov/clinic/epc/. Accessed: October 30, 2008.
2 Egger M, Davey Smith G. Principles of and procedures for systematic reviews. Egger M, Davey Smith G, Altman DG, editors. Systematic reviews in health care: meta-analysis in context. London. BMJ. 2001:23-42.
3 Reeves BC, Deeks JJ, Higgins JPT, et al. Including non-randomized studies. Higgins JPT, Green S, editors. Cochrane handbook for systematic reviews of interventions 5.0.1 [September 2008]. Chichester, UK. John Wiley & Sons, Ltd. 2008:391-432.
4 Norris SL, Atkins D. Challenges using nonrandomized studies in systematic reviews of treatment interventions. Ann Intern Med. 2005;142:1112-1119. [pmid: 15968036].
5 Higgins JPT, Green S. Cochrane handbook for systematic reviews of interventions 5.0.1 [September 2008]. Chichester, UK. John Wiley & Sons, Ltd. 2008.
6 Elm von E, Altman DG, Egger M, et al. The strengthening the reporting of observational studies in epidemiology (STROBE) statement: guidelines for reporting observational studies. PLoS Med. 2008;4(10):e296.
7 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27).
8 Black N. Why we need observational studies to evaluate the effectiveness of health care. BMJ. 1996;312:1215-1218. [pmid: 8634569].
9 Egger M, Davey Smith G, Schneider M. Systematic reviews of observational studies. Egger M, Davey Smith G, Altman DG, editors. Systematic reviews in health care: meta-analysis in context. London. BMJ. 2001:211-227.
10 Chou R, Helfand M. Challenges in systematic reviews that assess treatment harms. Ann Intern Med. 2005;142(12):1090-1099. [pmid: 15968034].
11 McCulloch P, Taylor I, Sasako M, et al. Randomised trials in surgery: problems and possible solutions. BMJ. 2002;324:1448-1451. [pmid: 12065273].
12 Reed D, Price EG, Windish DM, et al. Challenges in systematic reviews of education intervention studies. Ann Intern Med. 2005;142:1080-9. [pmid: 15968033].
13 Hartling L, McAlister FA, Rowe BH, et al. Challenges in systematic reviews of therapeutic devices and procedures. Ann Intern Med. 2005;142:1100-1111. [pmid: 15968035].
14 Furlan AD. Non-randomized studies: an evaluation of search strategies, taxonomy and comparative effectiveness with randomized trials in the field of low-back pain. University of Toronto. 2006.
15 MacLehose RR, Reeves BC, Harvey IM, et al. A systematic review of comparisons of effect sizes derived from randomised and non-randomised studies. Health Technol Assess. 2000;4(34):1-153. [pmid: 11134917].
16 Atkins D, Fink K, Slutsky J. Better information for better health care: the evidence-based practice center program and the agency for healthcare research and quality. Ann Intern Med. 2005;142(12):1035-1041. [pmid: 15968027].
17 Ray JG. Evidence in upheaval: incorporating observational data into clinical practice. Arch Int Med. 2002;162:249-254. [pmid: 11822916].
18 IOM (Institute of Medicine). The criteria and process for setting priorities In: Initial national priorities for comparative effectiveness research. Washington, DC. The National Academies Press. 2009:77-96.
19 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguishes efficacy from effectiveness studies. J Clin Epidemiol. 2006;59:1040-1048. [pmid: 16980143].
20 Rothman KJ, Greenland S, Lash TL. Modern epidemiology. 3rd ed. Philadelphia. Lippincott Williams & Wilkins. 2008.
21 Shadish WR, Cook TD, Campbell DT. Experimental and quasi-experimental designs for generalized causal inference. New York, NY. Houghton Mifflin Company. 2002.
22 Vandenbroucke JP. Prospective or retrospective: what’s in a name?. BMJ. 1991;302:249-250. [pmid: 1998787].
23 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-agency for healthcare research and quality and the effective health care program. J Clin Epidemiol. 2009. July 10. [ePub ahead of print].
24 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328:1490. [pmid: 15205295].
25 Anderson K, Boothby M, Aschenbrener D, et al. Outcome and structural integrity after arthroscopic rotator cuff repair using 2 rows of fixation. Am J Sports Med. 2006;34(14):1899-1905. [pmid: 16870821].
26 Carey TS, Evans A, Hadler N, et al. Care-seeking among individuals with chronic low back pain. Spine. 1995;20(3):312-7. [pmid: 7732467].
27 Creasey G, Grill J, Korsten M, et al. An implantable neuroprosthesis for restoring bladder and bowel control to patients with spinal cord injuries: A multicenter trial. Arch Phys Med Rehabil. 2001;82:1512-9. [pmid: 11689969].
28 DeVader SR, Neeley HL, Myles TD, et al. Evaluation of gestational weight gain guidelines for women with normal prepregnancy body mass index. Obstet Gynecol. 2007;110(4):745-51. [pmid: 17906004].
29 Davies HTO, Crombie IK, MacRae WA, et al. Audit in pain clinics, changing the management of low-back and nerve-damage pain. Anaesthesia. 1996;51:641-646. [pmid: 8758155].
30 Golden MP, Russell BP, Ingersoll GM, et al. Management of diabetes mellitus in children younger than 5 years of age. Am J Dis Child. 1985;139:448-452. [pmid: 3885716].
31 Leon A, Greenberg J, Kanuru N, et al. Cardiac resynchronization in patients with congestive heart failure and chronic atrial fibrillation. Effect of upgrading to biventricular pacing after chronic right ventricular pacing. J Am Coll Cardiol. 2002;39(8):1258-1263. [pmid: 11955841].
32 Scheurmier N, Breen AC. A pilot study of the purchase of manipulation services for acute low back pain in the United Kingdom. J Manipulative Physiol Ther. 2009;21(1):14-18. [pmid: 9467096].
33 Srinivasan S, Craig ME, Beeney L, et al. An ambulatory stabilisation program for children with newly diagnosed type 1 diabetes. Med J Aust. 2004;180:277-280. [pmid: 15012565].
34 Wilson TE, Fraser-White M, Feldman J, et al. Hair salon stylists as breast cancer prevention lay health advisors for african american and afro-caribbean women. J Health Care Poor Underserved. 2008;19:216-226. [pmid: 18263997].
35 Walter SD, Eliasziw M, Donner A. Sample size and optimal study desings for reliability studies. Stat Med. 1998;17:101-110. [pmid: 9463853].
36 Donner A, Eliasziw M. Sample size requirements for reliability studies. Stat Med. 1987;6:441-448. [pmid: 3629046].
37 Eliasziw M, Young SL, Woodbury MG, et al. Statistical methodology for the concurrent assessment of interrater and intrarater reliability: using goniometric measurements as an example. Phys Ther. 1994;74(777):788.
38 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. 1977;33:159-174. [pmid: 843571].
39 Devereaux PJ, Manns BJ, Ghali WA, et al. Physician interpretations and textbook definitions of blinding terminology in randomized controlled trials. JAMA. 2001;285:2000-2003. [pmid: 11308438].
40 White C, Bailar JI. Retrospective and prospective methods of studying association in medicine. Am J Pub Health. 1956;46:35-44.
41 Vandenbroucke JP, von Elm P, Altman DG, et al. Strengthening the Reporting of Observational Studies in Epidemiology (STROBE): Explanation and Elaboration. PLoS Med. 2007;4(10):e297. [pmid: 17941715].
42 Kleinbaum DG, Kupper LL, Morgenstern H. Epidemiologic research: principles and quantitative methods. New York, NY. John Wiley & Sons, Inc. 1982:57-58.
43 Brown C, Hofer T, Johal A, et al. An epistemology of patient safety research: a framework for study design and interpretation. Part 2. Study design. Qual Saf Health Care. 2008;17:163-169. [pmid: 18519621].
44 Design algorithm for studies of health care interventions. Available at: http://www.cochrane.dk/nrsmg/docs/chap2fig.gif. Accessed January 15, 2009.
45 Minnesota EPC (personal communication).
46 World Cancer Research Fund. Systematic Literature Review Specification Manual—version 15. Available at; http://www.dietandcancerreport.org/?p=slr_specification_manual.
47 Campbell DT, Stanley JC. Experimental and Quasi-Experimental Designs for Research. Rand McNally. Chicago, Illinois. 1966.
48 Furlan AD, Tomlinson G, Jadad AR, et al. Methodological quality and homogeneity influenced agreement between randomized trials and nonrandomized studies of the same intervention for back pain. Journal of Clinical Epidemiology. Mar. 2008;61(3):209-231. [pmid: 18226744].
49 American Dietetic Association. Evidence Analysis Manual, Steps in the ADA Evidence Analysis Process. 2009.
50 Gartlehner G, Lohr KN, Linda Lux, et al. “Study Taxonomy and Glossary,” unpublished material from the RTI-University of North Carolina. Evidence-based Practice Center. North Carolina. 2005.
51 Effective Public Health Practice Project (EPHPP). 2007. Quality assessment tool for quantitative studies dictionary. McMaster University Faculty of Health Sciences, School of Nursing. Available at: http://www.myhamilton.ca/myhamilton/CityandGovernment/HealthandSocialServices/Research/EPHPP/. Accessed December 1, 2010.
52 Figueiras A, Tato F, Takkouche B, et al. An algorithm for the design of epidemiologic studies applied to drug surveillance. Eur J Clin Pharmacol. 1997;51(6):445-448. [pmid: 9112057].
53 Reeves BC. A framework for classifying study designs to evaluate health care interventions. Forsch Komplementarmed Klass Naturheilkd. 2004;11(Suppl 1):13-17. [pmid: 15353897].
54 Estabrooks C, Goel B, Thiel E, et al. Decision aids: are they worth it? A systematic review. Journal of Health Services Research and Policy. 2001;6(3):170-182. [pmid: 11467275].
55 Wong CA, Cummings GG. The relationship between nursing leadership and patient outcomes: a systematic review. Journal of Nursing Management. 2007;15:508-521. [pmid: 17576249].
56 Lee H, Cummings GG. Factors influencing job satisfaction of front line nurse managers: a systematic review. Journal of Nursing Management. 2008;16:768-783. [pmid: 19017239].
57 Zaza S, Wright-De Aguero LK, Briss PA, Truman BI, Hopkins DP, Hennessy MH, Sosin DM, Anderson L, Carande-Kulis VG, Teutsch SM, Pappaioanou M. Data collection instrument and procedure for systematic reviews in the Guide to Community Preventive Services. Am J Prev Med. 2000;18(1S):44-74. [pmid: 10806979].
58 Heinsman DT, Shadish WR. Assignment methods in experimentation: when do nonrandomized experiments approximate answers from randomized experiments?. Psychological Methods. 1996;1(2):154-169.
59 Shadish WR, Matt GE, Navarro AM, Phillips G. The effects of psychological therapies under clinically representative conditions: a meta-analysis. Psychological Bulletin. 2000;126(4):512-529. [pmid: 10900994].
60 Cummings G, Estabrooks CA. The effects of hospital restructuring that included layoffs on individual nurses who remained employed: A systematic review of impact. International Journal of Sociology and Social Policy. 2003;23(8/9):8-53.
61 Cummings G, Lee H, MacGregor T, Davey M, Wong C, Paul L, Stafford E. Factors contributing to nursing leadership: a systematic review. Journal of Health Services Research and Policy. 2008;13(4):240-248. [pmid: 18806183].
62 Brown C, Hofer T, Johal A, Thomson R, Nicholl J, Franklin BD, Lilford RJ. An epistemology of patient safety research: a framework for study design and interpretation. Part 3. End points and measurement. Qual Saf Health care. 2008;17:170-177. [pmid: 18519622].
63 Brown C, Hofer T, Johal A, Thomson R, Nicholl J, Franklin BD, Lilford RJ. An epistemology of patient safety research: a framework for study design and interpretation. Part 4. One size does not fit all. Qual Saf Health Care. 2008;17:178-181. [pmid: 18519623].
64 Cook TD, Shadish WR, Wong VC. Three conditions under which experiments and observational studies produce comparable causal estimates: new findings from within-study comparisons. Journal of Policy Analysis and Management. 2008;27(4):724-750.