# Methods

The Steering Committee for this project was composed of Kenneth Bond (UAEPC), Donna Dryden (UAEPC), Lisa Hartling (UAEPC), Krystal Harvey (UAEPC), P. Lina Santaguida (McMaster EPC), Meera Viswanathan (RTI-UNC EPC), and Karen Siegel (AHRQ). The roles and credentials of individual members are listed in Appendix A.

A revision of the second objective made by the Steering Committee meant that the methods implemented during the course of this project differed slightly from those originally specified in the project work plan. Specifically, we had planned to select two taxonomies for further testing; however, none of the tools we identified incorporated the full range of nonrandomized study designs that commonly appear in systematic reviews of interventions and exposures. Consequently, instead of selecting two tools for further testing, the Steering Committee decided to select one tool and to modify it to better meet the needs of systematic reviewers.

## Identification of Taxonomies (Objective 1)

In order to compile a sample of classification tools, representatives from all EPCs and other research organizations, as well as individuals with expertise in this area, were identified by the Steering Committee. Individuals were contacted by email and asked to send any taxonomies, guidelines, or other systems used to classify study designs. The organizations contacted are listed in Appendix B and the sample letter of request appears in Appendix C. The 15 EPCs were also asked to provide examples of intervention or exposure studies where the assignment of study design had been problematic. The collection of these studies continued until the testing of the modified tool began.

## Selection of Taxonomies (Objective 2)

Five members of the of Steering Committee (DD, PS, MV, KB, LH) collaboratively developed six criteria for assessing the classification tools based on the experience of the EPCs and on individual knowledge regarding the characteristics considered desirable in a classification tool. The six criteria were:

- ease of use (e.g., contains a logic that users can readily follow);
- unique classification for each study design (no overlap);
- unambiguous nomenclature and decision rules/definitions (if applicable);
- comprehensiveness (complete in terms of the range of study designs);
- potentially allows for identification of threats to validity and provides a guide to strength of inference; and,
- developed by a well-established organization.

The five raters independently reviewed the tools collected in Objective 1 and ranked them according to their ability to satisfy the six criteria. The rankings were individually presented in a teleconference and an overall ranking was discussed until consensus was achieved between the five members.

## Development of the Taxonomy Tool (Objective 3)

The top-ranked tool was modified to incorporate relevant elements of the other tools and to ensure comprehensiveness in terms of study designs. Three members of the Steering Committee (KB, DD, LH) modified the tool using an iterative process. Ten studies25–34 identified in Objective 1 were purposefully selected to highlight some challenges in study design classification and to represent a range of designs. These studies and challenges were considered in modifying the tool. Decisions to modify the tool were based on the collective experience of the Steering Committee members. After several iterations of this process, the final version of the modified tool was used to produce a glossary of study design definitions and related concepts. The tool and accompanying glossary were sent to all members of the Steering Committee for review.

In preparation for testing the tool, 30 studies were selected from the pool of 71 studies that were received from three EPCs (47 studies from Minnesota EPC, 16 from UAEPC, and 8 from McMaster University EPC). Two members of the Steering Committee (LH, KB) who were not involved in developing the reference standard (see below Objective 4) selected the sample studies that would be used to test the new tool. Studies were selected to cover all of the key decision nodes within the algorithm in order to ensure adequate testing of the tool. Further, at least one study of each design was included in the sample pool. For the majority of designs (all but two—case-control and cross-sectional) at least two sample studies were included. Additional studies were included for the designs that we felt to be more commonly encountered in systematic reviews of therapeutic interventions and exposures (e.g., before-after studies, controlled before-after studies, and cohort studies). The selection of studies was based on the design determined by LH and KB, which was not consistent in all cases with the final reference standard classification. According to the reference standard classification, all decision nodes and all but two designs (prospective cohort, nested case control) in the taxonomy were represented.

## Taxonomy Testing and Development of Reference Standard (Objective 4)

Six individuals from the UAEPC tested the tool by applying it to the sample of 30 studies. The number of testers was based on previous work in this area14 and published guidelines for reliability studies.34–37 We selected testers with a range of experience and training in identifying study designs to reflect a cross-section of the resources typically available when producing an evidence report. Three testers had master’s level training in epidemiology, one had a master’s degree in a health science field, and two had undergraduate degrees in a health science or related field. The testers were given the 30 studies (Appendix D), the tool, and the accompanying glossary (Appendix E) with minimal additional instruction or direction. They were told that it would take approximately 5 to 10 hours to categorize the 30 studies and were asked to complete the assignment over a 2-week period. The study design names in the tool and glossary were masked and letter codes were used in their place in an attempt to have testers work through the flow diagram in a systematic fashion rather than relying on study design labels. This is supported by recommendations from the Cochrane Collaboration to focus on study design features rather than study design labels when assessing studies for inclusion in a systematic review.3

Concurrently, the sample of 30 studies, the tool, and the accompanying glossary were given to three members of the Steering Committee (DD, PS, VM) to develop the reference standard (i.e., the “true” classification for each study). After independently classifying the studies, the three reviewers met by teleconference to discuss disagreements and reach consensus.

We recorded the number of studies for each level of agreement (i.e., all testers agreed, 5 of 6 testers agreed, etc.). Inter-rater reliability was calculated using Fleiss’ kappa (κ). Fleiss’ κ was used as there were more than two raters; however, Fleiss’ κ tends to be lower when there are a large number of possible categories. In this case, there were 13 possible classifications which is considered large. Inter-rater reliability was calculated separately for (1) the testers and (2) the reference standard raters before consensus. We also calculated inter-rater reliability based on the formal training of the testers (completed relevant graduate training vs. currently undertaking graduate training). We then calculated the accuracy of the testers against the reference standard classifications of study designs. The mean time taken to classify the sample of studies and the mean time per study for the testers were also calculated.

Due to the low level of agreement for both the testers and the reference standard raters, we believed that it was important to further modify the tool to enhance its usefulness and usability in the context of a systematic review. We conducted semi-structured interviews independently with each tester to gather information on their general impressions of the tool; how they applied the tool; what items they found confusing; and, what aspects of the process they found challenging (e.g., an unclear or confusing tool vs. complex studies). The feedback from these interviews and from the reference standard raters was used to modify the tool. The changes that were made to the algorithm and glossary between the two rounds of testing are detailed in Appendix F.

A second round of testing was conducted to evaluate the modified tool (Appendix G). We selected six testers from the UAEPC. Three of the testers were involved in the first round of testing and three had not been previously involved. The three testers that were involved in the first round received no feedback after the first round of testing and were not aware of the reference standard design classifications of the sample of studies used for testing. Of these three testers, two had graduate level training in epidemiology and one had undergraduate training in a health-related field. Our strategy for selecting testers was similar to Round One. Specifically, we selected testers with a range of training (completed relevant graduate training vs. currently undertaking graduate training). Four of the testers received the flow diagram with the study design labels. This was based on the feedback we received from the testers in Round 1, indicating a preference for unmasked labels, identifying the conventional names of the study types. In order to allow for a comparison between the changes in the algorithm between Round 1 and Round 2, exclusive of unmasking the study design labels, two testers received the flow diagram with letter codes masking the study design labels. A random sample was selected of 15 of the 30 studies used for the first round of testing. As per the first round of testing, the testers were given the 15 studies, the modified tool, and the accompanying glossary. They were told that it would take up to 5 hours to classify the studies and were asked to complete the assignment within a week.

The same analyses were conducted for the second round of testing. These included calculations of agreement (number of studies with different levels of agreement between reviewers), inter-rater agreement (Fleiss’ κ), and accuracy against the reference standard. The agreement was calculated for the testers overall, by level of training, by participation in the first round of testing, and whether the study designs were labeled or coded. We calculated the mean time taken to classify the sample of studies and the mean time per study.