# Changes Made Between Round One and Round Two Algorithm

Round One | Round Two
Was there a comparison between interventions/exposures/observations (including before and after measurements on the same individuals)? | Was there a comparison to assess the effect/association of an intervention/exposure and an outcome? This could be between ≥ 2 groups or within the same individual or group(s) comparing pre- and post-intervention measures.
Were disease and exposure information assessed concurrently (e.g., by survey)? | Was information on the intervention/exposure gathered by the investigators concurrently (e.g., by survey)?
Was the study experimental (i.e., investigators had direct control over study conditions including decisions around allocation and timing of interventions)? | Was the study experimental (i.e., investigators had direct control over study conditions including: allocation to ≥ 2 interventions, timing of interventions, choice of outcome(s), and timing of outcome assessments?
Was more than one group compared? | Did all the participants receive the same intervention/exposure?
Was there a single cohort? | Did investigators identify the participants from a single source (e.g., same setting or time period)?
Were at least three measurements made before and after intervention/exposure? | Were there ≥ 3 measurements before and ≥ 3 measurements after the intervention/exposure?
Were at least three measurements made before and after intervention/exposure? | Were threre ≥ 3 measurements before and ≥ 3 measurements after the intervention/exposure?