# Bibliography and Summary of Studies for Classification (Objective 4)

Table D1 Characteristics of studies selected for classification

Study | Study design label^*^ | Study objective | Population | Intervention and comparator | Outcome(s)
Anderson 2006 | Before-after | To investigate the outcomes and structural integrity of the arthroscopic repair of rotator cuff tears using 2 rows of fixation | Patients with full-thickness rotator cuff tears that could be restore to anatomical position on the greater tuberosity | Arthroscopic rotator cuff repair using 2 rows of suture anchors | Functional scores and evidence of retear or defect
Bentas 2003 | Non-comparative | To evaluate the da Vinci surgical system for laparoscopic radical prostatectomy for prostate cancer | Adult patients with prostate cancer and eligible for radical prostatectomy | da Vinci surgical system | Operative morbidity (e.g., surgical time, blood loss, hospitalization), post-operative complications
Blais 2003 | ITS with comparison group | To evaluate impact of a cost-sharing drug insurance plan for people receiving social assistance | Quebec residents receiving social assistance | Residents receiving social assistance vs. privately insured residents | Monthly consumption of medications
Boszotta 2004 | Before-after | To evaluate arthroscopically assisted rotator cuff repair | Patients who received arthroscopically assisted transosseous rotator cuff repair | Arthroscopically assisted transosseous rotator cuff repair | Function scores
Cardo 1997 | Case-control | To identify risk factors for the transmission of HIV to health care workers after percutaneous exposure to HIV-infected blood | Healthcare workers with documented exposure to HIV-infected blood | Workers who subsequently became seropositive vs. those who did not | Personal information, information on source patient and injury
Carey 1995 | Cross-sectional | To determine the prevalence of chronic low back pain and the extent to which treatment is sought | Adults who had experienced back pain within the last 2 years | NA | Demographics and clinical characteristics, types of care sought, types of treatment received
Chenot 2006 | Non-comparative | To explore factors associated with acupuncture treatment for low back pain and the association of acupuncture with use of other health care services | Adult patients with low back pain being seen by general practitioners | NA | Use of pharmacologic and nonpharmacologic treatments for low back pain
Cherkin 2002 | Non-comparative | To describe patients and problems seen by CAM practitioners | Licensed acupuncturists, chiropractors, massage therapists, and naturopathic physicians | NA | Patient and practice characteristics (e.g., role of practitioner in path of care, reason for and duration of visit)
Cranson 1991 | CBA | To investigate the effect of Transcendental Meditation™ and TM-Sidhi™ programs on IQ scores and reaction time | First-year university students enrolled in a psychology course | Participation in daily TM and TM-Sidhi programs vs. nonparticipation in TM and TM-Sidhi programs | Cattel’s Culture Fair Intelligence Test and Hick’s reaction time
Darai 2002 | Retrosp cohort | To assess complications and cure rates of tension-free vaginal tape (TVT) procedure with or without hysterectomy | Women treated with stress urinary incontinence who had undergone TVT procedure alone or TVT with vaginal hysterectomy | TVT procedure alone vs. TVT procedure combined with vaginal hysterectomy | Post-operative urinary flow and subjective cure rate
Davies 1996 | Before-after | To identify and promote appropriate changes in management of low back pain and nerve-damage pain | Patients suffering from low back or nerve-damage pain attending outpatient pain clinics | Active feedback (mailed report and personal visit) of variations in practice within and between clinics | Changes in practice
DeVader 2007 | Retrosp cohort | To investigate the relationship between gestational weight (GW) gain and adverse pregnancy outcomes among women with normal prepregnancy body mass index (BMI) | Women with normal prepregnancy BMI who delivered full-term singletons | Lower than recommended GW vs. recommended GW vs. more than recommended GW | Adverse pregnancy outcomes
Happ 2008 | NonR trial | To investigate the impact of a systematically implemented assistive communication intervention with nonspeaking ICU patients and their nurse caregivers using a control group comparison | ICU nurses and nonspeaking ICU patients | Basic communication skills training (BCST) vs. BCST and assistive communication strategies vs. usual care | Observational measures of nurse-patient communication performance
Harris 1996 | ITS with comparison group | To determine whether the first 5 waves of English fundholding practices have reduced their prescribing costs relative to non-fundholding practices | All general practices in England | Fundholding practices vs. nonfundholding practices | Changes and rates of change in cost per prescribing unit and changes in number of items per prescribing unit
Herman 2001 | Before-after study | To evaluate the effect of transanal endoscopic microsurgery on anorectal motility and continence control and to define potential risk factors of post-surgical anorectal dysfunction | Adults with mobile rectal tumors qualifying for surgery | NA | Anorectal vector volume manometry, sphincter reflex evaluation, and barostat study
Hollabaugh 1998 | CBA | To evaluate incontinence rates after radical retropubic prostatectomy | Men with clinically localized prostate cancer | Modified radical retropubic prostatectomy vs. standard anatomic retropubic prostatectomy | Assessment of continence (dryness)
Kaplan 1996 | Non-concurrent cohort | To compare safety and efficacy of fascial vs. vaginal wall slings in the management of women with intrinsic sphincter deficiency (ISD) | Women who underwent surgical repair of ISD | Fascial sling vs. vaginal wall sling | Incontinence and patient satisfaction
Karlsson 2006 | Non-concurrent cohort | To evaluate maxillary molar distalization and anchorage loss in 2 groups before and after eruption of second maxillary molars | Children receiving orthodontic treatment | Distal movement performed before eruption of second molar vs. simultaneous movement of first and second molars | Cephalometric measures (e.g., maxillary base, molar position and inclination)
Leclercq 2000 | Before-after | To compare long-term clinical effects of permanent biventricular pacing in patients with stable sinus rhythm or chronic atrial fibrillation | Adults with with dilated cardiomyopathy and intraventricular conduction delay | Implanted permanent cardiac biventricular pacemaker | QRS duration and axis, NYHA class, LV ejection fraction, and peak VO_2_
Lipscomb 2003 | ITS without comparison group | To evaluate changes in rates and severity of falls from elevations among union carpenters after fall prevention standard change | Union carpenters working in Washington state between 1989–1998 who worked at least 3 mo. | Rates before vs. rates after enactment of standard change | Injuries, paid lost time due to falls from elevation, mean direct payments for falls from heights
Minassian 2005 | Before-after | To compare success and complication rates of the tension-free vaginal tape between patients with good vs. poor followup | Women with stress urinary incontinence | Tension-free vaginal tape procedure | Absence of stress urinary incontinence
Paulson 2004 | Non-concurrent cohort | To compare wait time and number of patients who leave without being seen between triage systems that use nurses vs. unlicensed assistive personnel | Patients presenting to the emergency department | Patient triage by nurses vs. by unlicensed assistive personnel | Wait time and number patients leaving without being seen
Qin 2002 | CBA | To evaluate potential benefits of regular Tai Chi Chuan exercise on the weight-bearing bones of postmenopausal women | Postmenopausal women who practice Tai Chi Chuan regularly and nonexercising controls | Tai Chi Chuan vs. no exercise | Bone mineral density
Scheurmier 1998 | Non-concurrent cohort | To test the cost implications of recommendations for purchasing arrangements for low back pain in primary care settings | General practices purchasing manipulation services under National Health Service arrangements | Recommended purchasing arrangements vs. previous purchasing arrangement | Waiting time for first attendance, number of consultations, drug use and cost, recovery time, x-ray utilization and cost of care
Sit 2007 | NonR trial | To determine the effectiveness of a community based stroke prevention program in improving knowledge about stroke, improving self-monitoring, and maintaining behavioral changes for stroke prevention | Adults with diagnosed minor stroke who live independently and are cognitively intact | Conventional medical treatment and community-based stroke prevention program vs. conventional medical treatment only | Lifestyle habits, medication compliance, and stroke knowledge
Verrotti 1993 | Non-concurrent cohort | To investigate whether quality of metabolic control is related to knowledge of disease | Children with type 1 diabetes mellitus | Diabetes education started at diagnosis vs. education started after diagnosis | Blood glucose control
Wells 2008 | Cross-sectional | To examine associations between neighborhood design and walking | Women partnered with Habitat for Humanity neighborhood developments | Neo-traditional neighborhoods vs. conventional suburban neighborhoods | Environmental characteristics (e.g., street networks, land use), walking
Wickizer 2004 | Retrosp cohort | To evaluate the effect of a publicly sponsored drug-free workplace program on reducing the risk of occupational injuries | Private companies insured through the Department of Labor and Industries | Companies participating and not participating in the drug-free workplace program | Injury rates, work time lost due to serious injury
Wilson 2008 | RCT | To assess the effectiveness of breast cancer health promoting messages administered by salon stylists to clients in the salon setting | Hair salons in urban minority area | Salons promoting health messages vs. salons not promoting health messages | Conduct of monthly breast self-exam, mammogram, receipt of information on breast health
Zancanato 1990 | RCT | To evaluate the effect of disodium cromoglycate and albuterol on energy cost of running in children with exercise-induced asthma | Children with mild to moderate exercise-induced asthma | Exercise test with premedication vs. exercise test without premedication | FEV_1_, peak VO_2_, energy cost of running, ventilation

CAM=complementary and alternative medicine; CBA=controlled before-after; ITS=interrupted time series; NonR trial=nonrandomized trial; RCT=randomized controlled trial; prosp=prospective; retrosp=retrospective; ITS=interrupted time series; RCT=randomized controlled trial

* Study design label is that assigned by the reference standard.

Anderson K, Boothby M, Aschenbrener D, et al. Outcome and Structural Integrity After Arthroscopic Rotator Cuff Repair Using 2 Rows of Fixation. Am J Sport Med. 2006;34(14):1899-1905.
Bentas W, Wolfram M, Jones J, et al. Robotic Technology and the Translation of Open Radical Prostatectomy to Laparoscopy: The early frankfurt experience with robotic radical prostatectomy and one year follow-up. Eur Urol. 2003;44:175-181. [pmid: 12875935].
Blais L, Couture J, Rahme E, et al. Impact of a cost sharing drug insurance plan on drug utilization among individuals receiving social assistance. Health Policy. 2003;64:163-172. [pmid: 12694953].
Boszotta H, Prünner K. Arthroscopically assisted rotator cuff repair. Arthroscopy. 2004;20(6):620-626. [pmid: 15241314].
Cardo DM, Culver DH, Ciesielski CA, et al. A case-control study of HIV seroconversion in health care workers after percutaneous exposure. The N Engl J Med. 1997;337(21):1485-1490.
Carey TS, Evans A, Hadler N, et al. Care-seeking among individuals with chronic low back pain. Spine. 1995;20(3):312-317. [pmid: 7732467].
Chenot J-F, Becker A, Leonhardt C, et al. Determinants for receiving acupuncture for LBP and associated treatments: a prospective cohort study. BMC Health Serv Res. 2006;6(149).
Cherkin DC, Deyo RA, Sherman KJ, et al. Characteristics of visits to licensed acupuncturists, chiropractors, massage therapists, and naturopathic physicians. J Am Board Fam Pract. 2002;15(6):463-472. [pmid: 12463292].
Cranson RW, Orme-Johnson DW, Gackenbach J, et al. Transcendental meditation and improved performance on intelligence-related measures: Longitudinal study. Pers Individ Dif. 1991;12(10):1105-1116.
Darai E, Jeffry L, Deval B, et al. Results of tension-free vaginal tape in patients with or without vaginal hysterectomy. Eur J Obstet Gynecol Reprod Biol. 2002;103:163-167. [pmid: 12069741].
Davies HTO, Crombie IK, MacRae WA, et al. Audit in pain clinics, Changing the management of low-back and nerve-damage pain. Anaesthesia. 1996;51:641-646. [pmid: 8758155].
DeVader SR, Neeley HL, Myles TD, et al. Evaluation of Gestational Weight Gain Guidelines for Women With Normal Prepregnancy Body Mass Index. Obstet Gynecol. 2007;110(4):745-751. [pmid: 17906004].
Happ MB, Sereika S, Garrett K, et al. Use of the quasi-experimental sequential cohort design in the Study of Patient-Nurse Effectiveness with Assisted Communication Strategies (SPEACS). Contemp Clin Trials. 2008;29:801-808. [pmid: 18585481].
Harris CM, Scrivener G. Fundholders’ prescribing costs: the first five years. BMJ. 1996;313:1531-1534. [pmid: 8978232].
Herman RM, Richter P, Walega P, et al. Anorectal sphincter function and rectal barostat study in patients following transanal endoscopic microsurgery. Int J Colorectal Dis. 2001;16:370-376. [pmid: 11760898].
Hollabaugh RS, Dmochowski RR, Kneib TG, et al. Preservation of putative continence nerves during radical retropubic prostatectomy leads to more rapid return of urinary continence. Urology. 1998;51:960-967. [pmid: 9609634].
Kaplan SA, Santarosa RP, Te AE. Comparison of fascial and vaginal wall slings in the management of intrinsic sphincter deficiency. Urology. 1996;47:885-889. [pmid: 8677582].
Karlsson I, Bondemark L. Intraoral Maxillary Molar Distalization, Movement before and after Eruption of Second Molars. Angle Orthod. 2006;76(6):923-929. [pmid: 17090171].
Leclercq C, Victor F, Alonso C, et al. Comparative Effects of Permanent Biventricular Pacing for Refractory Heart Failure in Patients with Stable Sinus Rhythm or Chronic Atrial Fibrillation. Am J Cardiol. 2000;85:1154-1156. [pmid: 10781772].
Lipscomb HJ, Li L, Dement J. Work-Related Falls Among Union Carpenters in Washington State Before and After the Vertical Fall Arrest Standard. Am J Ind Med. 2003;44:157-165. [pmid: 12874848].
Minassian VA, Al-Badr A, Pascali DU, et al. Tension-Free Vaginal Tape: Do Patients Who Fail to Follow-up Have the Same Results as those Who Do?. Neurourol Urodyn. 2005;24:35-38. [pmid: 15570579].
Paulson DL, Wash L. A Comparison of Wait Times and Patients Leaving Without Being Seen When Licensed Nurses Versus Unlicensed Assistive Personnel Perform Triage. J Emerg Nurs. 2004;30(4):307-311. [pmid: 15282506].
Qin L, Au S, Choy W, et al. Regular Tai Chi Chuan Exercise May Retard Bone Loss in Postmenopausal Women: A Case-Control Study. Arch Phys Med Rehabil. 2002;83:1355-1359. [pmid: 12370867].
Scheurmier N, Breen AC. A Pilot Study of the Purchase of Manipulation Services for Acute Low Back Pain in the United Kingdom. J Manipulative Physiol Ther. 2009;21(1):14-18. [pmid: 9467096].
Sit JWH, Yip VYB, Ko SKK, et al. A quasi-experimental study on a community-based stroke prevention programme for clients with minor stroke. J Clin Nurs. 2007;16:272-281. [pmid: 17239062].
Verrotti A, Chiarelli F, Sabatino G, et al. Education, knowledge and metabolic control in children with type 1 diabetes. Eur Rev Med Pharmacol Sci. 1993;15:5-10.
Wells NM, Yang Y. Neighborhood Design and Walking. Am J Prev Med. 2008;34(4):313-319. [pmid: 18374245].
Wickizer TM, Kopjar B, Franklin G, et al. Do Drug-Free Workplace Programs Prevent Occupational Injuries? Evidence from Washington State. Health Serv Res. 2004;39(1):91-110. [pmid: 14965079].
Wilson TE, Fraser-White M, Feldman J, et al. Hair Salon Stylists as Breast Cancer Prevention Lay Health Advisors for African American and Afro-Caribbean Women. J Health Care Poor Underserved. 2008;19:216-226. [pmid: 18263997].
Zanconato S, Baraldi E, Santuz P, et al. Effect of inhaled disodium cromoglycate and albuterol on energy cost of running in asthmatic children. Pediatr Pulmonol. 1990;8:240-244. [pmid: 2115156].