# Letter of Request To Identify Study Design Classification Tools

Hello [name of organization or person]:

The University of Alberta Evidence-based Practice Center (UAEPC) is undertaking a methods research project concerning classification of study designs for non -randomized studies. The UAEPC is one of 15 EPCs funded by the Agency for Healthcare Research and Quality (AHRQ) to review the available evidence and produce evidence reports on health care topics, and to conduct research on systematic review methodology. AHRQ is funding this methods project.

As part of this research project, the UAEPC in conjunction with two other EPCs—McMaster University and RTI-UNC—will 1) identify and test tools that have been developed to classify study designs in systematic reviews, and 2) recommend a classification tool that can be used by the EPCs and other systematic reviewers to bring consistency to the classification of non-randomized study designs.

In the first stage of this project, we are collecting different taxonomies, classification tools, guidelines or other systems that have been used when classifying study designs. To ensure that we have a broad spectrum of classification tools, we are wondering if you would send us any classification systems or tools that you have used or are aware of. If you are willing to send us these systems, please just reply to this email with the attachment or citation. If there are other individuals or organizations that you think may have useful information, please forward this e-mail, or send us their contact information and we would be happy to follow-up.

Thank you for any help you can provide.

Donna M. Dryden, Ph.D.

Associate Director, U of A/Capital Health Evidence-based Practice Center

University of Alberta

Aberhart Centre, Room 9417

11402 University Avenue

Edmonton, AB, Canada

Phone: (780) 492-1273

Fax: (780) 407-6435

Email: ddryden@ualberta.ca

Web site: http:\\www.epc.ualberta.ca