# Contacts for Identification of Study Design Classification Tools

Evidence-based Practice Centers:

- Blue Cross and Blue Shield Association, Technology Evaluation Center
- Duke University
- ECRI Institute
- Johns Hopkins University
- McMaster University
- University of Minnesota
- University of Oregon
- RTI International—University of North Carolina
- Southern California
- Tufts University—New England Medical Center
- University of Alberta
- University of Connecticut
- Minnesota EPC
- University of Ottawa
- Vanderbilt University

Additional organizations (and representatives where applicable):

- The Cochrane Collaboration Non-Randomized Studies Methods Group (Barney Reeves)
- The Campbell Collaboration (William Shadish)
- National Health Services (Richard Lilford)
- Faculty of Nursing, University of Alberta (Greta Cummings)
- Department of Educational Psychology, Faculty of Education, University of Alberta (Veronica Smith)
- Canadian Agency for Drugs and Technologies in Health
- American College of Physicians

Nine additional individual experts were identified and contacted. Names have been withheld.