# Steering Committee Members

Name | Affiliation | Training | Expertise | Role in project
Kenneth Bond | UAEPC | MA (Philosophy) | Project management, systematic review/health technology assessment methods | Technical expert
Donna Dryden | UAEPC | PhD (Epidemiology) | Epidemiology, systematic review methods | Co-task order leader
Lisa Hartling | UAEPC | MSc (Community Health and Epidemiology), PhD (Candidate, Pediatrics) | Epidemiology, systematic review methods | Co-task order leader
Krystal Harvey | UAEPC | BSc | Project coordination | Project coordinator
P. Lina Santaguida | McMaster EPC | PhD (Epidemiology) | Epidemiology, systematic review methods | Technical expert
Karen Siegel | AHRQ | PT, MA | Stakeholder perspective | AHRQ representative
Meera Viswanathan | RTI-UNC EPC | PhD | Research design, systematic review methods | Technical expert

UAEPC = University of Alberta Evidence-based Practice Center; AHRQ=Agency for Healthcare Research and Quality