# Appendixes

Appendix A Steering Committee Members

Appendix B Contacts for Identification of Study Design Classification Tools

Appendix C Letter of Request To Identify Study Design Classification Tools

Appendix D Bibliography and Summary of Studies for Classification (Objective 4)

Appendix E Round One Algorithm and Glossary

Appendix F Changes Made Between Round One and Round Two Algorithm

Appendix G Round Two Algorithm and Glossary

Appendix H Top Ranked Classification Tools Design