# Review

In this section, we review various formal approaches to prioritizing health research, including both methods discussed in the literature and methods applied in practice, with a focus on the use of VOI to prioritize systematic reviews. Part 1 first briefly discusses theoretical approaches to research prioritization with a focus on the principles of VOI and its conceptual elements. This part then defines and discusses alternative approaches to calculating VOI, and discusses how VOI estimates can inform decisions about research spending. Part 2 reviews the literature that has applied VOI to assess the value of clinical research studies, focusing on the methods applied in those studies. Part 3 reviews the processes that decisionmaking bodies and research funding agencies that perform and/or fund systematic reviews have used to set priorities among systematic reviews. We conclude that there is the potential, at least in theory, to systematically use VOI to inform priorities for systematic reviews.

## Part 1 Review of the Theoretical Approaches to Research Prioritization and VOI Analysis

### Approaches to Research Prioritization

Approaches to research prioritization, including the use of VOI analysis, differ in how they reflect objective and subjective elements in the priority-setting process, and how they measure or explicitly value health research. In general, opinions, judgments, and consensus among decision makers, experts and other stakeholders in health services provision and research form the basis for the subjective assessment and ranking of research. These qualitative assessments may be, and probably often are, informed by objective measures of the value of research. Objective measures include: (a) the burden of disease or costs of illness, (b) the “payback” from conducting and implementing research, (c) the welfare losses due to variations in clinical practice, and d) VOI.8,9 “Burden of disease,” “payback,” and “clinical variation” approaches view research as a means of improving practice by providing information for clinicians, policymakers and patients to help them make decisions about the implementation of particular treatments and interventions. These approaches, particularly measures of disease burden or costs of illness, use aggregate indicators across broad clinical domains rather than the incremental returns from addressing specific clinical questions when identifying priorities for health research. These approaches often consider whether there is some decision maker who might change their decision as the result of the information that could be generated. However, they often do not consider the uncertainty in the magnitude of the potential benefits of a change in decision, the likelihood that information would be generated that would suggest a change in decision would be desirable, or the likelihood that a decision would change even if the information obtained suggested that a change would be desirable (implementation). VOI analysis addresses these limitations by providing a formal framework for analyzing the value of additional information resulting from research to inform clinical or health policy decisions.5,6 By measuring the value of research in terms of health outcomes and resources forgone, VOI methods analyze research decisions using a common framework of health benefits and costs that are relevant to decisionmaking concerning health care.

### Principles of VOI and its Conceptual Elements

VOI analysis can provide estimates for the population expected value of information (pEVI) from health research. The pEVI in a particular research topic can be represented as a function of several multiplicative conceptual elements (Equation 1). These elements include the difference in benefits expected from alternative treatments or interventions on a per patient basis and the reduction in uncertainty therein, the implementation and durability of relevant information, and the size of the affected population of patients.

Equation 1 describes the population-level expected value of information (or pEVI). The equation is as follows: the population-level expected value of information is the sum over time of the product of 6 conceptual elements at each point in time- (begin six elements) beta to the exponent ‘t’, where beta is a discount factor between 0 and 1, multiplied by the durability of information at time ‘t’, multiplied by the size of the population affected by research at time ‘t’, multiplied by the difference between i) the sum over the set of interventions ‘j’ of the product of the probability of implementation of each intervention ‘j’ and the expectation over theta over the information set ‘I’ of the patient-level net benefit of these interventions, and ii) the sum over the set of interventions ‘j’ of the product of the probability of implementation of each intervention ‘j’ and the expectation over theta of the patient-level net benefits of these interventions without additional information (end six elements). p E V I = ∑_t_ β^t^ · D u r_t_ · P o p_j_ · ( ∑_j_ Im p_j t | I_ · E_θ / I_ N B ( j , θ ) - ∑_j_ Im p_j t_ · E_θ_ N B ( j , θ ) ) Equation 1

The specific conceptual elements of VOI are delineated in further detail below.

#### Difference in Benefits and Reduction in Uncertainty

For research to have value in informing decisionmaking in health care, individual studies or systematic reviews must infer that the benefits between treatments or other health interventions differ and the research must change uncertainty in these benefits. Accordingly, VOI quantifies the expected value of information from research on a per patient basis (EVI) as the improvement in net benefit that is expected from a particular set of information (I) on uncertain parameters θ with which to decide among j ∈[1,2,...,J] mutually exclusive interventions (Equation 2).

Equation 2 describes the expected value of information (or EVI) from research on a per-patient basis. The equation has two terms. The first term describes the expected value of the patient-level expected net benefit after information has been collected. The second term is subtracted from this, and describes the patient-level expected net benefit of the best decision given the current information set. The equation is as follows: EVI equals (begin first term) the expectation over the information set ‘I’ of the maximum over the set of interventions ‘j’, of the expectation of theta given the information set ‘I’ of the patient-level net benefit, which is a function of theta and ‘j’ (end first term). Subtracted from this is the second term, that is, the maximum over the set of interventions ‘j’ of the expectation over theta of the patient-level net benefit, which is a function of theta and ‘j’. E V I = E_I_ max_j_ E_θ | I_ N B ( j , θ ) - max_j_ E_θ_ N B ( j , θ ) Equation 2

Even though the analysis of net benefit may be limited to the differences expected in terms of health outcomes (E_θ_O(j,θ)) (e.g., life expectancy or QALYs), this is done perhaps most meaningfully on the basis of net monetary benefits in which costs (E_θ_C(j,θ)) are also considered in the choice for particular treatments and health interventions^1^. To do so, the health outcomes of the interventions under comparison are expressed in monetary terms by using some threshold value or willingness-to-pay for a unit of health outcome. The value of information at the population level, that is expected to come from research projects can be directly compared across different diseases, clinical conditions, other uses of resources, and with the costs of research, to inform research decisions.^2^

1 The expected net monetary benefit of treatment or intervention j with uncertain parameters θ equals the expected health outcomes, multiplied by some threshold value or willingness-to-pay for a unit of health outcome (λ), less the costs that are expected to be associated with this particular intervention, i.e., E_θ_NB(j,θ ) = λ · E_θ_O(j,θ) − C_θ_(j,θ). Alternatively, the expected net health benefit can be calculated as the expected outcomes in health less the health outcomes that could be obtained by applying the costs of treatment or intervention j in a health intervention or program that is at the cost-effectiveness threshold [10].

2 Notably, net monetary benefits measures, or its equivalent net health benefits, assume that diverse health outcomes and costs can be meaningfully analyzed in a utilitarian framework.

#### Probability of Implementation

Research only produces value when it leads to the implementation of more beneficial treatments or interventions than those provided on the basis of existing information. However, the provision of new evidence by itself may not ensure that the results of research are fully implemented into clinical practice. The extent to which this takes place is influenced by the knowledge and behaviors of health professionals, uptake or compliance by patients, and other contextual factors, such as the capacity to provide health services, and coverage or payment policies. Because of the dynamic and contingent nature of the implementation process, the probability of implementation is expected to vary over time (Im p_jt(|I)_ ∈[0,1]). Imperfect or delayed implementation of relevant information decreases the net benefit expected from research at a population level.11–13

##### Durability of Information

Another conceptual element that impacts the population value of research is the probability that relevant information on a particular treatment or intervention is durable over time

(Dur_t_ ∈[0,1]). This durability of information generally is associated with the rate at which new clinical evidence and/or better alternatives for patient management emerge. For example, future research, and systematic reviews in particular, may have less value in the presence of numerous trials or other research studies that are expected to produce valuable insights into the research topic being addressed within the near future. Another example in which durability is more likely to be limited is when there is a rapid followup of modifications to procedures and techniques. This commonly occurs in clinical domains such as device development. Conversely, information on elements of fundamental human biology, such as the natural history of a clinical condition, may have more durable effects.

##### Size of Patient Population

In establishing a population-level statistic to inform research decisions, VOI should account for the size of the population of patients expected to benefit from research (Pop_j_ ∈[0,∞]). Along with the prevalence and incidence of a particular disease or clinical condition, the value of particular studies or systematic reviews varies with the scale of the at-risk population in whom it could be applied. Although research may have value on a global scale, the population VOI is most often calculated for the population of patients within the specific jurisdiction or health system within which the research is being considered. In calculating the value of research, some consideration may also be paid to the practical effects of research activities across interventions and populations. In practice, if VOI estimates are to be compared across potential research topics, it is essential that the estimates being compared refer to the same population of potential beneficiaries of research (e.g., patients in the relevant jurisdiction(s)). Time preference is also typically reflected in population-level value of research by discounting the future benefits from research with rate β^t^ ∈[0,1] over the time period t for which a clinical or health policy decision is deemed relevant.

In the absence of information on these conceptual elements of VOI, it may be difficult to fully implement VOI. For example, this is the case when it is unclear as to what extent a particular study or systematic review is likely to produce information on set of outcomes and their associated probabilities that could affect the uncertainty in the expected benefits of alternative health interventions. Similarly, it may be difficult to predict the durability of new evidence or predict how the results of research will impact clinical practice. Performing VOI with incomplete information typically requires making assumptions about the missing information or limiting the objective of the analysis. In effect, VOI analysis may be limited to calculating the value expected from perfect information. The expected value of perfect information (EVPI) and expected value of partial perfect information (EVPPI) can provide upper bounds on the value of research through calculating the improvement in net benefit expected from eliminating all uncertainty in all parameters θ or a subset of these ϕ(∈θ), respectively.^3^ In contrast to full EVI calculations, more limited analysis such as that of the expected value perfect information requires information only about the distribution of (net) benefits of the interventions under consideration. Population level estimates for the value of perfect information are typically useful in identifying research priorities across disease areas or clinical domains and in quantifying the gaps in evidence on particular treatments or health interventions. However, because such measures provide only upper bounds, they can only establish necessary conditions for research spending and not sufficient conditions. In other words, bounding techniques can suggest that the expected value of a given type of research is small so that the research is unlikely to be worth performing. However, suggesting the research is worth performing requires the ability to actually estimate VOI.

3 EVPI is calculated as the difference in maximum net benefit expected from making a clinical or health policy decision from among j ∈ [1,2,.., J] mutually exclusive treatments or interventions with perfect information and that with uncertain parameters θ, with EVPI = E_θ_ max_j_ NB(j,θ)−max_j_ E_θ_NB(j,θ).

The quantification of EVPPI for a particular parameter or subset of parameters ϕ∈θ, with ψ the remaining set of parameters, can be described as follows: EVPPI_ϕ_ = E_ϕ_ max_j_ NB_ϕ/ψ_(j,ϕ,ψ)−max_j_ E_θ_ NB(j,θ )

### Approaches to Calculating VOI

A variety of approaches can be used to calculate the value of information expected from health research, including “full modeling,” “minimal modeling,” “maximal modeling,” and “conceptual VOI.” These approaches typically vary in the extent to which modeling is complex and costly. The complexity of modeling is determined by the analytic efforts and data required to apply the approach. Even though more complex models may provide more accurate estimates of the VOI for particular research topics, it is often difficult to present these models and their assumptions transparently. Besides cost differences in terms of staff time, data input and other resources necessary for model implementation, the approaches to calculating VOI may also differ in terms of their potential for application in a given context, and the speed with which the analysis can be completed. Table 1 summarizes the full modeling, minimal modeling, maximal modeling and conceptual approaches to VOI, their requirements and potential scope for application, and their advantages and disadvantages.

Table 1 Approaches for calculating value of information in research topics in health care

Approach | Definition | Requirements | Clinical Application(s) | Advantages (+) and Disadvantages (−)
Full Modeling^§^ | Full characterization of disease/treatment using a decision model or other simulation model of relevant health states | - Structuring of model, data input for each model parameter | - Individual research topics, within single disease area or clinical domain; - Chronic conditions, complex diseases | − High costs of performing VOI in individual research topics; − Complex and time-consuming modeling exercises; + Accurate uncertainty analysis and VOI estimates, including calculation of EVPPI
Minimal Modeling, Subtype ‘No modeling’^§^ | Direct replication or direct computation of (incremental) effects on comprehensive health outcomes (e.g., life expectancy or QALYs), costs and/or net benefits | - Distributions of comprehensive health outcomes or QALYs, costs and/or net benefits | - Individual research topics, within single disease area or clinical domain; - Acute conditions, end of life treatments; - Direct measurement of final health outcomes and resource use | + Low costs of performing VOI in individual research topics; + Does not involve complex and time-consuming modeling; + Complementary to adaptive research design; − Requires clinical trial or data set that can provide comprehensive measure of net benefit; − No comprehensive uncertainty analysis and VOI estimates (EVPPI)
Minimal Modeling, Subtype ‘Limited Modeling’^§^ | Any modeling necessary (e.g., modeling of patient survival, mapping of treatment effect to utilities or approximation of costs) without using a decision model or other simulation model of relevant health states | - Intermediate measures for health outcomes or QALYs, costs, and/ or net benefits; life expectancy or survival data | - Individual research topics, within single disease area or clinical domain; - Acute conditions, end of life treatments | + Reduced costs of performing VOI in individual research topics; + Reduced need for complex and time-consuming modeling; + Complementary to adaptive research design; − Requires clinical trial or data set that can require only modeling of survival or other limited modeling to generate comprehensive measure of net benefit; − No comprehensive uncertainty analysis and VOI estimates (EVPPI)
Maximal modeling^§^ | Comprehensive modeling organized around clusters of individual but related topics (e.g., disease, meta- or multi-purpose models) | - Clustering of research topics and description of clinical relation, correlation in information about net benefit in/across different interventions/topics; - Structuring of model, data input for each model parameter | - Multiple research topics, within or across disease areas or clinical domains; - Chronic conditions, complex diseases, disease management or integrated care | + Potential for minimal costs of performing VOI in individual research topics; + Accurate uncertainty analysis and VOI estimates, including calculation of EVPPI; + Potential for building an infrastructure for value of research calculations that would facilitate rapid and low-cost VOI estimates to aid future prioritization and planning of research; − Highly complex and time-consuming modeling exercises; − Requires evidence that captures correlation in information between individual research topics
Conceptual VOI | Bounding exercise using information on the conceptual elements of VOI^†^ | - Quantitative evidence of zero or low value in potential difference in net benefit, reduction expected in uncertainty, probability of implementation, durability of information, or size of patient population | - Individual or multiple research topics, within or across disease areas or clinical domains; - Any application, e.g., rare diseases, controversial treatment, active R&D | + No costs of performing VOI in individual or multiple research topics; + Rapid indication of informative bounds on value of research; − Requires evidence that any of the conceptual elements of VOI equals zero or low values; − Potential for inaccurate uncertainty analysis and VOI estimates

EVPPI: expected value of partial perfect information; QALYs: quality-adjusted life-years; R&D: research and development; VOI: value of information

§ In all modeling approaches, VOI calculations can be based on simulation/bootstrapping (parametric and/or non-parametric) or equation-based computations (parametric).

† The results of existing VOI studies may also provide information bounds on VOI in particular research topics, depending on the applicability of these studies to the specific context or setting in which decisions about the priority of the research topics are made.

#### Full Modeling

VOI calculations commonly involve full modeling of a particular disease or clinical condition, its treatment and the different health states to characterize the uncertainty in the benefits of treatment or health interventions under consideration. This may be performed using decision trees, Markov models, or discrete event simulation. In such modeling exercises, patient characteristics, risk attributes and transition probabilities are structured such that predictions of disease progression and patient survival can be provided. This produces estimates for the probability of specific health states that can be combined with quality of life or utility estimates and costs in those health states which can be used to generate a wide set of comprehensive outcomes measures, including life expectancy, QALYs and costs or net benefits, that address clinical decisionmaking or health policy decisions.

Rich characterization in full decisions models, within which all potential sources of uncertainty are promulgated, allows for detailed assessment of VOI that can identify how information about specific parameters might have value in addressing the clinical question, and establish efficient research designs. However, the complexity of constructing such models makes full modeling VOI sufficiently time-consuming and costly that they may be impractical for many purposes, including that for prioritizing low-cost studies, such as systematic reviews.

#### Minimal Modeling

Minimal modeling approaches to VOI can be defined as those approaches that allow the calculation of VOI for individual research topics without constructing a full decision model of the disease and treatment process.7 Two subtypes of minimal modeling can be distinguished: “no modeling” and “limited modeling.”

“No modeling” VOI can be applied when existing research provides data on comprehensive outcome measures that are sufficient to address the clinical or health policy decision in question from the decisionmaking perspective adopted. Such comprehensive outcome measures may include health outcomes (e.g., life expectancy or QALYs), costs, and/or net benefits. For example, in a trial of treatment alternatives in which QALY differences were measured in patients until death, and the preference for treatment is based on QALYs, those QALY differences would be considered a comprehensive outcome measure. In such a case, direct replication of these raw data through bootstrapping or simulation would allow for calculating the value in further research studies, including systematic reviews. Alternatively, VOI can be based on equation-based computations for which parametric distributions on the comprehensive outcomes are to be specified. Aside from its practical application in end of life treatment, “no modeling VOI” may also be particularly feasible in acute diseases and short-symptom conditions.

In “limited modeling” VOI, a particular treatment or intervention affects morbidity but not mortality, and quality of life measures are directly available so that the quality of life measure can be easily combined with survival data to calculate the value of research. Modeling can then be limited to predicting patient survival or life expectancy and combining it with the quality of life data. A recent analysis of the value of research on atypical antipsychotics is an example of such a limited modeling VOI study.14 Depending on the evidence available from existing research and the clinical or policy decision in question, modeling to provide VOI estimates may also be limited to mapping treatment effects to utilities or approximating cost differences in treatments or health intervention under consideration.

In comparison with full modeling approaches, “limited” and “no” modeling VOI have less ability to accurately analyze the value of studying specific parameters that may partially determine the benefits of the intervention alternatives being considered. That is, the value of partial information (EVPPI and/or pEVPPI ) can only be assessed in the data on the comprehensive outcome measures that are used as input for the minimal modeling exercise. Moreover, “minimal” models cannot be tailored to different clinical setting or decisions contexts by manipulating the parameters of a model. On the other hand, VOI analysis with only minimal modeling significantly reduces the burden of VOI application, particularly in terms of the costs of staff time needed to construct and analyze a complex model. This makes it possible to consider its potential use to inform priorities for studies that are not very costly, such as systematic reviews.

#### Maximal Modeling

Instead of constructing separate models for the analysis of the value of research in individual topics, a maximal modeling approach to VOI uses a single comprehensive model to simultaneously inform priorities in multiple research topics that can be clustered within or across clinical domains. Such a “maximal model” is often organized around a particular disease or condition or health care program, in which the clustering of separate but related topics most commonly follows from the pathogenesis or pathophysiology of a disease or conditions, its natural progression, and treatment patterns or clinical pathways. The Coronary Heart Disease Policy Model is an example of a comprehensive model that simulates demographics and risk-factor-epidemiology, which includes disease history, to project the incidence, morbidity, mortality and costs of coronary heart disease (CHD) in the U.S. population. This model could be used to address many questions about the value of research in a broad range of CHD interventions, including control of hypertension, hypercholesterolemia, and acute treatment of myocardial infarction.15 The complexity and data demands of maximal modeling approaches to VOI are as great as or greater than those of full modeling approaches. Accordingly, maximal modeling approaches can provide estimates of VOI for specific parameters in much the way that full modeling approaches can provide such estimates.

Maximal modeling VOI is typically useful in chronic or complex diseases in which a patient’s health is affected by multiple related clinical conditions and interventions. In effect, the use of maximal models will perhaps be of greatest practical value in identifying priorities for research in disease-areas for which there are multiple interventions that could be pursued simultaneously. When modeling the value of research in topics that cluster with other research topics, it is important to account for potential correlation in information across these topics so as to establish the benefits of different types of research, especially in the context of other types of research.^4^ In some cases, information to address a particular research topic or clinical question may come from a combination or a series of complementary studies. For example, as opposed to relying on a single study, combining the results from a trial reporting the effect of a particular treatment on relevant outcomes along with observational data on prevalence and natural history of a disease and cost studies may be used to address issues of comparative effectiveness of alternative ways for patient management. Accounting for correlation and future prospects in research may be of particular relevance in valuing systematic reviews or other evidence synthesis studies, as these may often also be performed to identify relevant evidence gaps and to inform future research decisions related to sequential trials or adaptive research designs.16 Because of the potential computational burden, more complete modeling approaches may have to rely on meta-modeling concepts or network analyses.17,18 The main advantage of maximal modeling approach to VOI in this is that the costs of VOI calculations can be defrayed over multiple research topics. This may justify establishing infrastructure, perhaps building on existing decision models, to perform value of research calculations in a domain that can facilitate rapid and low-cost assessment of VOI for future topics.

4 The value that can be expected from research in multiple separate but related topics can never be larger than the value that could come from research in this domain that would otherwise be found from completely resolving a target disease or condition in a particular patient population.6

#### Conceptual VOI

In a conceptual approach to VOI, information is used about each of the multiplicative elements of VOI to assess the value of research studies without formally quantifying the value of information through modeling exercises. As described in Equation 1, the elements that go into conceptual VOI include the differences in benefits expected from different treatment or intervention options at patient level, the expected change in uncertainty about these benefits from obtaining more evidence, the implementation and durability of relevant information, and the size of the population of patients affected from research. Evidence collection on these different elements can be performed through various means, including the use of expert elicitation, as shown in Table 2. If information indicates that any of the conceptual elements of VOI has a value that is zero or close to zero, the product of these terms, and hence the VOI, will likely approximate zero. Unless the value of some other element is exceptionally large, this indicates that further research, including VOI modeling, is unlikely to be valuable.

Table 2 Checklist for collecting evidence for conceptual VOI to prioritizing health research

Element of Conceptual VOI | Operationalization of Elements | Representative Variables | Potential Sources for Evidence
Difference in Benefits | - Potential for improvement in health outcomes, reduction of costs and perhaps improvement in net benefits? | Expected differences in health outcomes, including measures for mortality, morbidity and quality of life, resources, prices or costs, net benefits | Previous studies, MEDLINE^®^/PubMed, expert elicitation
Reduction in Uncertainty | - Relevant studies with comparative information available?; - Significant uncertainty in decisionmaking?; - Potential for ambiguity in evidence? | Standard deviation or error, confidence interval, probability or likelihood in health outcomes, costs and perhaps net benefits | Previous studies, MEDLINE^®^/PubMed, expert elicitation
Probability of Implementation | - Potential for improvement in implementation by health professionals and/or patients?; - Potential for overcoming financial or organizational barriers?; - Potential for controversy in making decisions about best practice?; - Variability in diffusion of health technologies and significant variation in clinical practice? | Technology diffusion, uptake implementation, (appropriate) use, adherence, compliance, variation in practice, patterns of care | MarketScan data, MEDLINE^®^/PubMed, postmarketing surveillance, expert elicitation
Durability of Information | - Forecasts of emergence of valuable new health technologies?; - Potential for new evidence to become available?; - Represents valid outcomes for clinical practice? | Time frame for decisionmaking, rates of technology development, validity of evidence | Expert elicitation
Size of Patient Population | - Significant disease burden or large proportion of patients within a specific jurisdiction? | Prevalence and incidence of disease, size of patient population | National Statistic Bureaus, National Health Institutes, expert elicitation

VOI: value of information

Examples in which conceptual VOI may indicate a limited value of research include rare diseases where the population of patients affected from research is too small to justify research spending on performing VOI. In such cases, the conceptual VOI approach may also be applied to multiple topics simultaneously. The idea that a disease is too rare to justify research based on expected population benefit should not be construed as evidence that research is never justified. Instead, it argues that priorities in research topics with low conceptual VOI may have to be justified on the basis of measures other than VOI.

### Use of VOI Estimates To Inform Research Decisions

By comparing the population-level expected value of information (pEVI) with the expected costs of research, the returns from particular research studies and systematic reviews can be assessed. Equation 3 describes the population-level returns expected from a set of information I produced by new research (Π_I_). These returns depend on the benefits and costs of particular research projects (C_It_)^5^ and on the costs of performing VOI to identify research priorities (C_VOI_)^6^.

5 Aside from the costs of setting up and conducting research studies, research may also incur costs for using up patients in (randomized) research and delaying decisionmaking until research reports. In effect, the likely short duration of performing and reporting systematic reviews may in part explain why this type of research is inexpensive relative to trials and other (observational) studies, and increasingly used to inform clinical and health policy decisions.

6 The approach to VOI affects costs in terms of its modeling requirements (e.g., staff and data input) as well as the opportunity costs compared with other approaches to research prioritization due to any delay in decisionmaking about research spending as a result of the time it takes to analyze VOI before particular research studies can commence.

Equation 3 describes the population-level returns from a set of information ‘I’ produced by new research. The equation is as follows: the population-level returns from a set of information ‘I’ produced by new research equals the population-level expected value of information from new research minus the sum over time of the costs of performing the research at time ‘t’, and minus the costs of performing value-of-information analysis as an approach to prioritizing and designing the research. ∏_I_ = p E V I - ∑_t_ β_t_ · C_I t_ - C_V O I_ Equation 3

In settings in which resources or budgets are fungible between research and other uses, it is possible that all studies for which the returns are expected to be positive are potentially worthwhile performing. However, when the resources for research are limited, only those (combinations of) primary studies or systematic reviews should be performed that maximize the expected returns of research across all potential research topics. In choosing between mutually exclusive studies in individual topics of research, efficient research designs can be established through choosing type of studies (e.g., trial versus systematic review), sample size, relevant outcomes, and the length of follow up for which the returns to research in terms of population health are maximized.19 In comparing estimates for VOI to prioritize among research projects, it is important that these estimates are standardized for key assumptions, including those related to the conceptual elements of VOI (e.g., relevant population) and discounting.7

## Part 2 Review of VOI Studies in the Literature

We conducted a comprehensive review of the literature to identify clinical research studies with some empirical application of VOI and to describe the methodology applied to estimate the value of research within those studies. Where possible, we focus on potential implications for the use of VOI in prioritizing systematic reviews.

### Methods

For our comprehensive review of the literature, we merged the results of a search for VOI studies in an earlier AHRQ report by the University of Chicago (UC) on Minimal Modeling Approaches to Value of Information Analysis for Health Research with the search results from the Duke Evidence-based Practice Center’s (DEPC) report on Evaluating the Potential Use of Modeling and Value-of-Information Analysis for Future Research Prioritization Within the Evidence-based Practice Program. Both searches yielded publications on VOI in health services/health care settings, in English, between 1990 and 2010 (Appendix A). We reviewed only those studies with some clinically related empirical application of VOI analysis, and excluded all hypothetical applications as well as studies with theory/methods only. More details on the inclusion criteria for potential relevant VOI studies and the process of screening the ones initially identified can be found in the above-mentioned reports.20,21

We developed a form to standardize data extraction for the review of VOI applications (Appendix B). For each application in the VOI publications, we extracted data on the approach to modeling and consideration of information on the conceptual elements of VOI, the results of VOI analysis and the comparison with other VOI studies and other approaches to research prioritization. Data were extracted by one investigator [TH], whereas the other investigators performed a check for accuracy and completeness of the extracted data, with disagreements resolved by consensus. Through a descriptive analysis of the review results, we outline whether and how methods for VOI are currently applied for prioritizing systematic reviews.

### Results

#### Identification of VOI Studies

Figure 1 summarizes the process and results of our search for VOI applications in the literature. The MEDLINE^®^/Pubmed database searches in the UC report and the DEPC report produced 230 hits and 1196 hits, respectively. After screening the abstracts and titles of these hits, 120 studies were identified as potentially relevant VOI studies from the UC search, and 205 from the DEPC report. Based on the full-text reading of all these studies, the UC search revealed 21 VOI studies with hypothetical examples or theory/methods only, and 76 studies with some clinically related empirical application of VOI. 9,11–14,17,22–91 The DEPC report revealed one VOI application complementary to the UC report.92 Appendix C provides all the data extracted from the 72 VOI applications from in total 77 VOI studies included in our literature review.

Figure 1 Flowchart of the review of VOI studies

DEPC: Duke Evidence-based Practice Center; UC: University of Chicago; VOI: value of information

^†^ 13 of 72 VOI applications were reported in multiple VOI studies

^§^ In 3 additional VOI applications, insufficient information was available to review the methods applied

^‡^ In 1 additional VOI application, insufficient information was available to review the methods applied

Figure 1 is a flow chart that summarizes the search and selection of VOI applications in the literature. It begins with the total number of hits screened from both a previous MEDLINE search performed at the University of Chicago (UC) [21] and a Pubmed search by the Duke Evidence-Based Practice Center (DEPC) [20], and ends with the number of studies that had VOI applications based on different approaches to calculating VOI. In total, we found 40 VOI applications based on “full modeling” (i.e., 39 through the UC search and one additional one through the DEPC-search), 18 VOI applications based on “minimal modeling”, and 14 VOI applications based on “maximal modeling”. This figure is described further in the Section entitled “Results, Indentification of VOI Studies” as follows: “Figure 1 summarizes the process and results of our search for VOI applications in the literature. The MEDLINE®/Pubmed database searches in the UC report and the DEPC report produced 230 hits and 1196 hits, respectively. After screening the abstracts and titles of these hits, 120 studies were identified as potentially relevant VOI studies from the UC search, and 205 from the DEPC report. Based on the full-text reading of all these studies, the UC search revealed 21 VOI studies with hypothetical examples or theory/methods only, and 76 studies with some clinically related empirical application of VOI [9,11–14,17,22–91]. The DEPC report revealed one VOI application complementary to the UC report [92]. Appendix C provides all the data extracted from the 72 VOI applications from in total 77 VOI studies included in our literature review.”

#### Applications of VOI and the Approaches to Modeling

Table 3 summarizes details of the 72 clinically related empirical applications in the published VOI studies being reviewed. In 55 percent of the applications, a full model was constructed for performing VOI calculations. Minimal modeling or maximal modeling approaches were applied less frequently, 26 percent and 19 percent, respectively. The value of research was analyzed across diverse clinical domains with heart disease, cancers, infectious diseases, and mental disorders as the most common ones. The interventions under evaluation ranged from screening strategies for breast cancer and diagnostics in minor head injuries to antipsychotics and changes in health services provision for patients with hearing impairment.14,73,78,86 More than half of the studies were conducted in the U.K., 19 percent in the U.S., 10 percent in Canada, and 7 percent in The Netherlands. Eighty-one percent of the VOI applications were undertaken from a societal or health care system perspective, as one might expect given the public characteristics of evidence collection.

Table 3 Summary of the extracted data on the clinically related applications (N=72) in value of information studies (M=77)

| | n (n/N%)
Approach to Calculating VOI | Full Modeling | 40 (55%)
Approach to Calculating VOI | Minimal Modeling, Subtype ‘No Modeling’ | 9 (13%)
Approach to Calculating VOI | Minimal Modeling, Subtype ‘Limited Modeling’ | 9 (13%)
Approach to Calculating VOI | Maximal Modeling | 14 (19%)
Application | Heart Disease/Cardiovascular Disorders | 17 (24%)
Application | Cancer | 14 (19%)
Application | Infections | 7 (10%)
Application | Mental Disorders | 5 (7%)
Application | Asthma/COPD | 4 (6%)
Application | Trauma-related Disorders | 3 (4%)
Application | Diabetes/Obesity | 2 (3%)
Application | Other | 20 (28%)
Setting | U.S. | 14 (19%)
Setting | U.K. | 38 (53%)
Setting | Canada | 7 (10%)
Setting | The Netherlands | 5 (7%)
Setting | Other | 8 (11%)
Perspective | Societal | 20 (28%)
Perspective | NHS/NIH/Health care system | 38 (53%)
Perspective | Third party payer | 6 (8%)
Perspective | Other | 2 (2%)
Perspective | Not Stated | 6 (8%)
Purpose of VOI | Quantification of Decision Uncertainty and/or Overall Value of Further Research
Purpose of VOI | At Patient Level Only (i.e., EVPI) | 6 (8%)
Purpose of VOI | At Population Level Only (i.e., pEVPI) | 31 (43%)
Purpose of VOI | Both at Patient and Population Level | 24 (33%)
Purpose of VOI | Not Done | 11 (15%)
Purpose of VOI
Purpose of VOI | Analysis of Uncertainty in Element(s) of Decision and/or Particular Research Priorities
Purpose of VOI | At Patient Level Only (i.e., EVPPI) | 15 (21%)
Purpose of VOI | At Population Level Only (i.e., pEVPPI) | 24 (33%)
Purpose of VOI | Both at Patient and Population Level | 3 (4%)
Purpose of VOI | Not Done | 30 (42%)
Purpose of VOI
Purpose of VOI | Assessment of Value in Specific Research and/or Design of Particular Studies
Purpose of VOI | At Patient Level Only (i.e., EVI, EVSI, ENG, or ENBS) | 1 (1%)
Purpose of VOI | At Population Level Only (i.e., pEVI, pEVSI, pENG, or pENBS) | 6 (8%)
Purpose of VOI | Both at Patient and Population Level | 2 (3%)
Purpose of VOI | ICER_trial_ | 4 (6%)
Purpose of VOI | Not Done | 58 (82%)
Purpose of VOI
Purpose of VOI | Demonstration of Application of Method(s) | 24 (33%)
VOI Calculations with Evidence from Systematic Review(s) | Done | 43 (60%)
VOI Calculations with Evidence from Systematic Review(s) | Not Done/Not Stated | 29 (40%)
Application of VOI to Prioritize New Evidence Synthesis Research, including Systematic Review(s) | Done | 3 (4%)
Application of VOI to Prioritize New Evidence Synthesis Research, including Systematic Review(s) | Not Done/Not Stated | 67 (93%)
Application of VOI to Prioritize New Evidence Synthesis Research, including Systematic Review(s) | Not Applicable | 2 (3%)

COPD: chronic obstructive pulmonary disease; ENBS: expected net gain from sampling; ENG: expected net gain from trialing; EVPI: expected value of perfect information; EVPPI: expected value of perfect information for particular parameters; EVSI: expected value of sample information; ICER_trial_: incremental cost-effectiveness ratio of a particular trial; NHS: National Health Services; NIH: National Institutes of Health; pENBS: population expected net gain from sampling; pENG: population expected net gain from trialing; pEVPPI: population expected value of perfect information for particular parameters; pEVSI: population expected value of sample information; VOI: value of information.

The purpose of applying VOI varied across the VOI studies. Most applications (85%) sought to quantify the uncertainty in benefits associated with intervening in health care and/or the value of performing further research on particular treatments or interventions, with the results of the analyses mostly reported in terms of population measures for expected value of perfect information (EVPI). In fewer studies, VOI was also applied to analyze the value of studying individual or a subset of parameters with which to inform clinical or policy decisions (i.e., EVPPI and/or pEVPPI). Only 18 percent of the applications were set up to establish the expected value of particular types of studies and research designs, despite the potential relevance of such costs in decisions to fund specific clinical studies. Most published applications of VOI studies in health services/health care settings appear to be focused on demonstrating VOI methods rather than directly informing research priorities.

Although the value of research calculations often relied on evidence from systematic reviews (60%), VOI application studies occasionally recommended performing new systematic reviews as an implication of the analyses. In fact, recommendations to perform systematic review were stated only in 3 instances. Garside et al. identified areas of uncertainty related to patient management of Barrett’s esophagus for which further research synthesis might be focused.85 Fox et al. recommended reviews of evidence for predicting non-response to cardiac resynchronization therapy devices for patients with heart failure.61 The VOI analysis by Bojke et al. sought to address the appropriateness of the review and modeling of screening for age-related macular degeneration treatment in the U.K.80 Even though these studies suggested systematic reviews as the next step, we should note that they were not undertaken in order to motivate a systematic review but to inform priorities for other, more costly studies. This suggests that, even if a VOI is not performed in order to inform priorities for systematic review related to a topic, once a VOI is performed on a topic for some other reason (e.g., to develop a design for a clinical trial), the results of such a VOI might also provide information on the potential value of a systematic review. As a result, funders of systematic reviews, such as AHRQ, may wish to regularly monitor the literature of VOI to look for applications in clinical areas where topics may arise. If a VOI study is found in areas where a systematic review is being considered, it might then be used to inform the priority for that systematic review, either through a conceptual VOI approach or a more quantitative approach, including by being adapted to assess VOI for a systematic review.

In the review, the VOI methodology was found to vary across the applications. In all 58 applications of full or minimal modeling VOI, the analyses addressed single clinical research questions. Minimal modeling approaches were applied in those situations where VOI estimates could be provided from direct replication of comprehensive outcome measures through bootstrapping, or from limiting modeling to the approximation of patient survival or life expectancy, for example, using (declining) exponential distributions.^7^ The models in maximal modeling VOI applications typically described the process of screening, diagnosis and treatment of patients in particular disease areas, including bacterial infections.69,70 and coronary heart disease.71 However, all of these analyses restricted their VOI calculations to single research topics rather than simultaneously assessing the value of studying the different topics clustering within the maximal model. Maximal modeling or full modeling is often applied to provide overall measures of uncertainty and value of research in treatments of health interventions (e.g., EVPI or EVPPI), even though more limited modeling approaches could perhaps have been of use in these instances.

7 All values are standardized on historical currency exchange rates (http://www.oanda.com/currency/historical-rates [Accessed: 2012 Feb 10]) and consumer price index (http://www.bls.gov/data/inflation_calculator.htm [Accessed: 2012 Feb 10] but not on population size, time horizon of analysis, and cost-effectiveness threshold.

##### Use of Conceptual VOI and Comparison of Results

We did find evidence of the use of a conceptual approach to VOI prior to performing more complex VOI analyses. Indeed, VOI applications commonly cited uncertainty in differences in health outcomes and costs between the treatments or health interventions being studied (Table 4) as a prerequisite to justifying further analysis. In addition, the population of patients that was expected to benefit from further research was also frequently referenced. However, the implementation and durability of relevant information was almost never considered in advance of performing VOI. Because such information could have bounded the value of information that could come from both new research and further VOI modeling, the explicit consideration of information on these additional conceptual elements that determine the population-level value of information might have led to decisions not to pursue VOI in some cases, increasing the efficiency of investments in VOI.

Table 4 Summary of extracted data on the consideration of conceptual elements of VOI and comparison with other studies in clinically related empirical applications (n = 72) in value of information studies (m = 77)

| | Stated, referring to source(s) | Stated, based on assumption(s) | Stated, without any reference | Not Stated | Not Applicable
| | n (n/N%) | n (n/N%) | n (n/N%) | n (n/N%) | n (n/N%)
Consideration of Information on Conceptual Elements when Calculating VOI | Difference in Benefits | 37 (51%) | 4 (6%) | 4 (6%) | 26 (36%) | 1 (1%)
Consideration of Information on Conceptual Elements when Calculating VOI | Reduction in Uncertainty | 31 (43%) | 4 (6%) | 8 (11%) | 28 (40%) | 0 (0%)
Consideration of Information on Conceptual Elements when Calculating VOI | Probability of Implementation | 0 (0%) | 10 (14%) | 0 (0%) | 58 (81%) | 4 (6%)
Consideration of Information on Conceptual Elements when Calculating VOI | Durability of Information | 5 (7%) | 41 (57%) | 13 (18%) | 11 (15%) | 2 (3%)
Consideration of Information on Conceptual Elements when Calculating VOI | Size of Patient Population | 43 (60%) | 13 (18%) | 7 (10%) | 5 (7%) | 4 (6%)
Consideration of Information on Conceptual Elements when Calculating VOI
Consideration of Information on Conceptual Elements when Calculating VOI | Discounting | NA | NA | 42 (58%) | 28 (39%) | 2 (3%)
Consideration of Information on Conceptual Elements when Calculating VOI
Consideration of Information on Conceptual Elements when Calculating VOI | Existing VOI Studies | 2 (2%) | 0 (0%) | 0 (0%) | 64 (90%) | 5 (7%)
Comparison or VOI Results with Those of Other VOI Studies | | NA | NA | 5 (7%) | 62 (86%) | 5 (7%)
Comparison of VOI Results with Those of Other Approaches to Research Prioritization | | NA | NA | 9 (13%)^†^ | 62 (86%) | 1 (2%)

NA: Not applicable; VOI: value of information.

† Only 1 study was found in which the results of performing VOI was compared with other quantified measures for informing research priorities, i.e., research payback. 47

Another important finding of the review related to comparability across VOI studies. Indeed, we observed that it was often difficult to compare VOI estimates across all clinically related empirical applications of VOI. For example, the EVPI results varied from $0–$2.48 at the lower end 49,11[c],35,92[a] to $17,326 at maximum per patient,52 while the population values for EVPI ranged between $0-$37.54046,56[b],68[b] up to $308 billion.14, Aside from the fact that the models and their assumptions were not always reported transparently, a meaningful comparison was often difficult because of the variation in the perspective and time horizon of the analyses, the methods for measuring health outcomes, costs as well as VOI (e.g., pEVPI versus sample size calculations), and the threshold value for cost-effectiveness used in the applications for which the VOI analysis was performed. With exception of population size and discounting, VOI elements were not consistently considered as a standard for bounding population-level estimates of the value of research (Table 4). Specifically, VOI calculations were adjusted for the probability that research findings are implemented in only 14 percent of clinical applications, as measured by screening rates or medication compliance. The durability of new information was generally simply assumed that to vary between 5 and 20 years. The lack of comparability in existing VOI studies may explain why the results of VOI applications were seldom compared with those of other studies (7%).11[b],35,45,50,66 Standardization would make value of research calculations more comparable, and increase the ability of VOI to inform research priorities.

## Part 3 Review of the Priority-Setting Processes for Systematic Reviews in Practice

We reviewed the processes used to set priorities for among systematic reviews by major U.S. and international health care decisionmaking bodies and research funding agencies that are engaged in systematic review activities. This was done to understand how prioritization of systematic reviews proceeds in practice, and to examine whether VOI currently plays any role in this process.

### Methods

For our review of the practice of priority-setting, we assembled an initial list of potentially relevant organizations from (1) the recent AHRQ-commissioned reports by Meltzer et al. 21 and Myers et al., 20 (2) an earlier review of practical approaches to health technology assessment priority setting,93 and (3) consultation with a Technical Expert Panel convened to serve an advisory role on this project (Appendix D). This list was screened to identify those organizations that perform and/or fund systematic reviews as part of their research and/or decisionmaking activities. We reviewed only the processes of organizations that provided information in English and through Internet sources that was sufficiently detailed to allow their priority-setting processes to be meaningfully reviewed.

We developed a standardized form to extract data on the prioritization processes in the selected organizations (Appendix E). For each process, we extracted data related to the procedures and methods for research prioritization, including whether VOI was used, the stakeholders involved in the process, and the approach used for generating topics for systematic reviews. Data were extracted by one investigator [JS], whereas the other investigators performed a check for accuracy and completeness of the extracted data, with disagreements resolved by consensus (Appendix F). We limited our search for data to any reports that were publicly available from the Internet. Descriptive synthesis of the review results was performed to describe the priority-setting processes, focusing on any uses of VOI for prioritizing topics for systematic reviews.

### Results

#### Identification of the Priority-Setting Processes for Systematic Reviews

Figure 2 summarizes the process and results of identifying the priority-setting processes in health care organizations that perform and/or fund systematic reviews. Of the 72 organizations that were initially listed and screened for inclusion in our review, 64 were identified as unique. Only 24 of these organizations reported any information on systematic review activities, and 11 of these were eliminated because either insufficient or no documentation of their priority-setting processes was available online. In total, we reviewed the processes for setting priorities for systematic reviews for 13 different organizations, including organizations whose activities are directed towards national, regional and global populations (Table 5).

Figure 2 Flowchart of the review of priority-setting processes in health care organizations that perform and/or fund systematic reviews

AHRQ EHC: Agency for Healthcare Research and Quality Effective Health Care program; CADTH: Canadian Agency for Drugs and Technologies in Health; DEPC: Duke Evidence-based Practice Center; DERP: Drug Effectiveness Review Project; NICE: National Institute for Health and Clinical Excellence; NIHR HTA: National Institute for Health Research Health Technology Assessment program; OHTAC: Ontario Health Technology Advisory Committee; Osteba: Basque Office for Health Technology Assessment; SBU: Swedish Council on Technology Assessment in Health Care; SIGN: Scottish Intercollegiate Guidelines Network; TEP: Technical Expert Panel; UC: University of Chicago; USPSTF: U.S. Preventive Services Task Force; WHO: World Health Organization; ZonMw: Netherlands Organisation for Health Research and Development.

^*^ Note: ‘Insufficient’ documentation is defined as missing over 50% of information or categories included in the data extraction form.

Figure 2 is a flow chart that summarizes the search and selection of health care organizations that perform and/or fund systematic reviews that have sufficient documentations of their priority setting processes. It begins with the combined results of organziations screened from previous efforts by the University of Chicago staff [21], the Duke Evidence-based Practice Center [20], a publication by Noorani et al [93], and a recommendation by the Technical Expert Panel convened as part of this project. It ends with the idenification of 2 global and 11 national organizations that provide sufficient documentation of their priority setting process. This figure is described further in the Section entitled “Results, Identification of the Priority Setting Processes for Systematic Reviews” as follows: “Figure 2 summarizes the process and results of identifying the priority setting processes in health care organizations that perform and/or fund systematic reviews. Of the 72 organizations that were initially listed and screened for inclusion in our review, 64 were identified as unique. Only 24 of these organizations reported any information on systematic review activities, and 11 of these were eliminated because either insufficient or no documentation of their priority-setting processes was available online. In total, we reviewed the processes for setting priorities for systematic reviews for 13 different organizations, including organizations whose activities are directed towards national, regional and global populations (Table 5).”

Table 5 Selected health care decisionmaking bodies and research funding agencies

Organization (Jurisdiction) | Primary Purpose and Audience of Systematic Reviews | Annual Budget for Systematic Reviews^1^(2011 U.S. Dollars)
Agency for Healthcare Research Quality Effective Health Care Program [AHRQ EHC]^§^ (U.S.) [4,95] | Production of evidence on outcomes, comparative clinical effectiveness, and appropriateness of pharmaceuticals, devices, and health care services to inform health care decisions by practitioners, policymakers, and patients | $25 million [$0.08 per capita^2^
Canadian Agency for Drugs and Technologies in Health Technology Assessments [CADTH HTA]^§^ (Canada) [96,97] | Provision of information about effectiveness of drugs and other health technologies to decision makers on health policy and purchasing, service management, and clinical practice | $5.16 million [HTA-program] [$0.15 per capita^2^]
National Institute for Health and Clinical Excellence [NICE]^§^ (U.K.) [98] | Provision of guidance on public health, health technologies, and clinical practice to health professionals, National Health Services bodies and general public | ~$70 million [$1.12 per capita^2^]
National Institute for Health Research Health Technology Assessment programme [NIHR HTA]^§^ (U.K.) [99] | Production of research information on healthcare treatments and tests to practitioners, policymakers, and patients care as part of National Health Services. | $88 million [$1.14 per capita] [HTA-program] [94]
U.S. Preventive Services Task Force [USPSTF]^§^ (U.S.) [100] | Provision of recommendations on primary or secondary preventive services in primary care settings to primary care clinicians, policymakers, managed care organizations, public and private payers, quality improvement organizations, research institutions, and patients | ~$7.34 million [$0.02 per capita]
World Health Organization [WHO]^‡^ (NA) [101,102] | Provision of clinical information and development of practice guidelines to countries | NA
Cochrane Collaboration^‡^ (NA) [103] | Provision of evidence to inform decisions about human health care by healthcare providers, policymakers, patients, their advocates and carers | NA
Netherlands Organisation for Health Research and Development [ZonMw]^§^ (The Netherlands) [104] | Provision of information for evidence-based policymaking on the governmental level and promotion of evidence-based use of health technologies at practice level | ~$13.5 million [$0.81 per capita][94]
Scottish Intercollegiate Guidelines Network [SIGN]^§^ (Scotland) [105] | Provision of clinical Information to practitioners and development of practice guidelines | $0.5 million [$0.10 per capita] [94]
Swedish Council on Technology Assessment in Health Care [SBU]^§^ (Sweden) [106] | Provision of information to inform healthcare decisions by professional caregivers, healthcare administrators, planners, health policymakers, patients and their families | $9.5 million [$1.00 per capita] [HTA-program] [94]
Ontario Health Technology Advisory Committee [OHTAC]^§^ (Ontario, Canada) [107] | Provision of recommendations about adoption and coverage of health technologies by OHTAC | $2 million [$0.06 per capita] [HTA-program] [94]
Basque Office for Health Technology Assessment [Osteba]^§^ (Basque, Spain) [108] | Provision of information on safety, efficacy, effectiveness, accessibility, and equity about different technologies to inform policymaking by Health Department, and to improve medical practice and organization of healthcare delivery by hospitals, clinicians and private care providers | $2.3 million [$1.24 per capita] [HTA-program] [94]
Drug Effectiveness Review Project [DERP]^§^ (U.S.) [109,110] | Synthesis and judgment on clinical evidence for drug-class reviews for membership organizations. | $4.2 million [NA]

HTA: health technology assessment; NA: not applicable; U.S.: United States.

§ Serving national or regional populations

‡ Serving global populations

1 All budgets are standardized on historical currency exchange rates (http://www.oanda.com/currency/historical-rates [Accessed: 2012 Feb 10]) and consumer price index (http://www.bls.gov/data/inflation_calculator.htm [Accessed: 2012 Feb 10])

2 Based on population estimates from: http://en.wikipedia.org/wiki/List_of_countries_by_population; http://www.scotland.org/facts/population/; http://en.wikipedia.org/wiki/Basque_people (All, Accessed: 2012 Feb 10].

#### Prioritization of Systematic Review Topics in Practice

Across all the health care organizations we reviewed, systematic reviews are performed and/or funded to provide information on the expected benefits of diverse treatments and health interventions, and to inform clinical and health policy decisions. The results of systematic reviews are commonly made publicly available. None of the organizations responsible for priority setting among potential review topics directly serve as the main authorities or bodies responsible for clinical policy or coverage decisionmaking for their respective populations. As a result, recommendations about clinical guidance or coverage following systematic reviews are typically not tied directly to reimbursement decisions or policies.

The budgets for systematic review programs vary considerably, and these budgets generally come from public funds. Most commonly, these funds are used to directly employ researchers so that the reviews and synthesis of evidence are performed by the priority-setting organizations themselves. By standardizing on population size (in 2011 U.S. dollars), we found that the review budgets ranged from around $0.02 to $1.24 per capita across the different populations served. These estimates are difficult to compare because the reported budgets for systematic review often pertain to the overall budget allocated for health technology assessment and the actual number of systematic reviews, or spending on systematic reviews, is not generally reported^8^. Nonetheless, the different decisionmaking bodies and research funding agencies may have divergent economic and political considerations regarding the use of systematic reviews as a means to inform decisionmaking in health care in their respective jurisdictions. In most organizations, budget spending on systematic reviews requires some prioritization alongside other (research) activities, including the development of clinical practice guidelines and provision of consumer-oriented materials on health care, and clinical/health services research.

8 The number of ongoing research projects, which may include systematic reviews, is reported to vary between 9 projects [OHTAC] and 180 projects [ZonMw].94.

The different processes for priority setting among systematic reviews generally comprise some form of criteria-based assessment and ranking of review topics. As one might expect, prioritization criteria commonly relate to burden of disease, the benefits expected from the treatments or health interventions under study and the feasibility, including costs, of performing systematic reviews. Although stakeholders are often reported to be engaged in the priority-setting processes, e.g., by inclusion in prioritization committees or panels, how their input is directly reflected in establishing priorities is generally not well-described. Regardless, prioritization decisions are often made with some consideration of ethical, legal, and social implications as well as public interest. Perhaps to this end, the prioritization of topics for systematic review is often reported to be done through some form of qualitative assessment or subjective judgment, using processes that can include informal discussions, voting, or iterative ranking exercises.

#### Use of VOI in Prioritizing Systematic Reviews

In the prioritization processes undertaken by the different organizations with systematic review activities, most of the criteria relating to the conceptual elements of population-level VOI are reported as being taken into consideration (Table 6). Only the durability of review findings is less often (23%) reported as a criterion for prioritization decisions, although the timeliness or relevance of reviews and the future availability of treatment alternatives are considered in some instances (i.e., CADTH, NICE, and Osteba). The measures of VOI are operationalized in different ways, and very limited discussion is provided as to what types of information or data are developed on these measures and how this evidence is used to make prioritization decisions. AHRQ and CADTH both discuss the production of initial briefing reports on each potential topic that include information relevant to VOI-related criteria, but specific indicators for these criteria these are not described. None of the 13 organizations we reviewed provided guidance for using some type of analysis in which the elements of VOI are quantified and combined to prioritize potential systematic review topics, and none reported performing VOI to formally quantify the value of systematic reviews. This may perhaps not be surprising given that VOI analyses are often complex and often focus on demonstrating methods, as discussed in our review of the literature.

Table 6 Summary of the reported use and operationalization of conceptual elements of VOI for systematic review topics in priority-setting processes of the different organizations under review (K=13)

Conceptual Ele Elements of VOI | Difference in Benefits | Reduction in Uncertainty | Probability of Implementation | Durability of Information | Size of Patient Population
Reported Use, k (k/K%) | 11 (92%) | 6 (46%) | 8 (62%) | 3 (23%) | 6 (46%)
Operationalization
AHRQ EHC [4,95] | “Represents a significant disease burden” | “Represents important uncertainty for decision makers” | “Exists within a clinical, consumer, or policymaking context that is amenable to evidence-based change” | Not stated | “…affects health care decisionmaking… for a large proportion [or priority] of the U.S. population”
CADTH HTA [96,97] | “Prevalence, incidence, DALE, HYs of LE, economic burden or other relevant measurement of disease burden) of the population affected by changes to policy” | Not stated | Potential for assessment to inform decisions given rate of change in clinical practice and receptor capacity by policymakers” | “Alternatives currently or soon to be available for the conditions that this technology addresses” | “prevalence, incidence…of the population”
NICE [98] | “Does the proposed guidance address a condition which is associated with significant morbidity or mortality in the population as a whole or in particular subgroups?” | “Would guidance promote the best possible improvement in public health and wellbeing and/or patient care, and the reduction of inequalities in health, given available resources?” | “Would publication of formal guidance make a significant difference to improving the effectiveness of public health programmes or interventions?” | “Would guidance still be relevant and timely at the expected date of publication ...?” | Not stated
NIHR HTA [99] | Not stated | ‘What are the benefits in terms of reduced uncertainty? This could concern: outcomes for patients” | “How long before benefits could be realised, bearing in mind time taken to perform the assessment and affect a change in practice?” | Not stated | “Other factors including... prevalence of the condition “
USPSTF [100] | “whether the topic address a disease with a substantial health burden” | “New evidence (e.g., new studies or new analyses of previous data) that has the potential to change prior recommendations.” | “Potential for a recommendation to affect clinical practice (based on existing controversy or the belief that a gap exists between evidence and practice.” | Not stated | Not stated
WHO [101,102] | “Problems associated with a high burden of illness in low and middle-income countries, or new and emerging diseases.” | “No existing guidelines or recommendations of good quality” | “Implementation is feasible, will not exhaustively use available resources, and barriers to change are not likely to be so high that they cannot be overcome” | Not stated | Not stated
Cochrane Collaboration[103] | “Burden of disease, magnitude of problem and urgency’ | Not stated | “Achievability and resources required”, “opportunity for action” | “Timeliness’ | ‘Large scale impact on population’
ZonMW [104] | “Actual burden of disease given current treatment strategies” | Not stated | Not stated | Not stated | “Number of patients”
SIGN [105] | Not stated | “Areas of clinical uncertainty as evidenced by wide variation in practice and outcomes” | Not stated | Not stated | Not stated
SBU [106] | “The subject should have a significant impact on mortality and health” | Not stated | Not stated | Not stated | Not stated
OHTAC [107] | “Technology must improve the net health outcome and/or safety “ | Not stated | Not stated | Not stated | Not stated
Osteba [108] | “The difference in QALE between a patient who has the condition and receives conventional treatment and that of a person of same age who does not have the condition”“ | Not stated | “The expected effect of the results of the assessment on the outcome of illness for patients with the illness” | Not stated | “The number of people with the condition per 1,000 people in the general population”
DERP [109,110] | Not stated | Not stated | Not stated | Not stated | Not stated

AHRQ EHC: Agency for Healthcare Research and Quality Effective Health Care program; CADTH: Canadian Agency for Drugs and Technologies in Health; DALE: disease-adjusted life expectancy; DERP: Drug Effectiveness Review Project; HYs: health years; NICE: National Institute for Health and Clinical Excellence; NIHR HTA: National Institute for Health Research Health Technology Assessment program; LE: life expectancy: OHTAC: Ontario Health Technology Advisory Committee; Osteba: Basque Office for Health Technology Assessment; QALE: quality-adjusted life expectancy; SBU: Swedish Council on Technology Assessment in Health Care; SIGN: Scottish Intercollegiate Guidelines Network; USPSTF: U.S. Preventive Services Task Force; VOI: value of information; WHO: World Health Organization; ZonMw: Netherlands Organisation for Health Research and Development.

Topics for systematic review are usually generated through passive means such as through web nominations and/or consultations with experts. Even though some organizations report the use of environmental scans or literature searches, these methods typically serve to eliminate those topics for which systematic reviews have already been performed rather than to identify new review topics. Within the AHRQ Effective Health Care Program, recent initiatives have been undertaken to enhance the process of generation topic through scans of information sources and the engagement with relevant stakeholders. 4,111 More systematic approaches to topic generation would reveal more topics with potential for systematic review, and make prioritizing among these using formal methods like VOI even more important.

## Conclusion

Though VOI methods have received extensive attention, VOI measures have not been used explicitly to inform priority setting in systematic reviews. The 77 VOI studies in the literature focus heavily on the demonstration of methods rather than the use of VOI in research prioritization. Full modeling is the dominant approach in VOI studies, even though minimal modeling using comprehensive outcome measures or constructing a maximal model could be used as practical approach in many cases. When such analyses are presented, there is no evidence that conceptual approaches to VOI were applied before deciding to invest resources in performing a more expensive full modeling VOI study. In publicly available descriptions of the priority-setting processes of 13 major U.S. and international organizations engaged in systematic review activities, we found that VOI was not used to inform priorities for systematic reviews. However, with the exception of durability of benefits, we did find that prioritization discussions often implicitly considered elements that affect VOI (i.e., differences in benefits and expected reduction in uncertainty, probability of implementation, durability of review findings, and the size of the affected patient population). Also, even when elements of VOI were considered, we found very little discussion of how elements were quantified or integrated into a framework that is consistent with VOI principles. Decisions about the focus of health research are typically made by qualitative assessment and subjective judgment processes in which a broad perspective is adopted so as to reflect the different values and preferences of stakeholders in the prioritization process. Thus, there has been little attention to whether the use of VOI can improve processes for prioritizing systematic reviews and how VOI might be most efficiently applied to do so. However, if efforts, such as that of the AHRQ’s Effective Health Care (EHC) Program, to generate more potential topics for systematic review continue, resources to perform systematic reviews will likely not keep pace with the topics generated, and tools such as VOI that might help prioritize among topics may be of increasing importance.