# References

1 Laupacis A, Straus S. Systematic reviews: time to address clinical and policy relevance as well as methodological rigor. Annals of Internal Medicine. 2007;147(4):273-4. [pmid: 17638716].
2 Chambers D, et al. Maximizing the impact of systematic reviews in health care decision making: a systematic scoping review of knowledge-translation resources. Milbank Q. 2011;89(1):131-56. [pmid: 21418315].
3 Perrier L, et al. Interventions encouraging the use of systematic reviews by health policymakers and managers: A systematic review. Implement Sci. 2011;6(1):43. [pmid: 21524292].
4 Whitlock EP, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective healthcare program. J Clin Epidemiol. 2010;63(5):491-501. [pmid: 19540721].
5 Claxton K. Bayesian approaches to the value of information: implications for the regulation of new pharmaceuticals. Health Economics. 1999;8(3):269-74. [pmid: 10348422].
6 Meltzer D. Addressing uncertainty in medical cost-effectiveness analysis implications of expected utility maximization for methods to perform sensitivity analysis and the use of cost-effectiveness analysis to set priorities for medical research. Journal of Health Economics. 2001;20(1):109-29. [pmid: 11148867].
7 Meltzer DO, et al. Minimal Modeling Approaches to Value of Information Analysis for Health Research. Med Decis Making. 2011;31(6):E1-E22. [pmid: 21712493].
8 Fleurence RL, Torgerson DJ. Setting priorities for research. Health Policy. 2004;69(1):1-10. [pmid: 15484602].
9 Philips Z, et al. Priority setting for research in health care: an application of value of information analysis to glycoprotein IIb/Illa antagonists in non-ST elevation acute coronary syndrome. International Journal of Technology Assessment in Health Care. 2006;22(3):379-87. [pmid: 16984067].
10 Stinnett AA, Mullahy J. Net health benefits: a new framework for the analysis of uncertainty in cost-effectiveness analysis. Med Decis Making. 1998;18(2 Suppl):S68-80. [pmid: 9566468].
11 Fenwick E, Claxton K, Sculpher M. The value of implementation and the value of information: combined and uneven development. Medical Decision Making. 2008;28(1):21-32. [pmid: 18263559].
12 Hoomans T, et al. Value of information and value of implementation: application of an analytic framework to inform resource allocation decisions in metastatic hormone-refractory prostate cancer. Value in Health. 2009;12(2):315-24. [pmid: 18657098].
13 Willan AR, Eckermann S. Optimal clinical trial design using value of information methods with imperfect implementation. Health Economics. 2010;19(5):549-61. [pmid: 19399753].
14 Meltzer DO, Basu A, Meltzer HY. Comparative effectiveness research for antipsychotic medications: how much is enough?. Health Aff (Millwood). 2009;28(5):w794-808. [pmid: 19622539].
15 Weinstein MC, et al. Forecasting coronary heart disease incidence, mortality, and cost: the Coronary Heart Disease Policy Model. Am J Public Health. 1987;77(11):1417-26. [pmid: 3661794].
16 Griffin S, Welton NJ, Claxton K. Exploring the research decision space: the expected value of information for sequential research designs. Med Decis Making. 2010;30(2):155-62. [pmid: 20040743].
17 Tappenden P, et al. Methods for expected value of information analysis in complex health economic models: developments on the health economics of interferon-beta and glatiramer acetate for multiple sclerosis. Health Technology Assessment (Winchester, England). 1. 2004;8(27):iii-78.
18 Ades AE, Mavranezouli I, et al. Network meta-analysis with competing risk outcomes. Value Health. 2010;13(8):976-83. [pmid: 20825617].
19 Conti S, Claxton K. Med Decis Making. Nov–Dec. 2009;29(6):643-60. Epub 2009 Jul 15. Dimensions of design space: a decision-theoretic approach to optimal research design. [pmid: 19605884].
20 Myers E, et al. Evaluating the Potential Use of Modeling and Value-of-Information Analysis for Future Research Prioritization Within the Evidence-based Practice Center Program. P.b.t.D.E.-b.P.C.u.C.N. 290-2007-10066-I. 2011. AHRQ Publication No. 11-EHC030-EF. Rockville, MD.
21 Meltzer D, et al. Minimal Modeling Approaches to Value of Information Analysis for Health Research, Methods Future Research Needs Report No. 6. 2011. AHRQ Publication No. 11-EHC062-EF. Rockville, MD.
22 Ramsey SD, Blough DK, Sullivan SD. A forensic evaluation of the National Emphysema Treatment Trial using the expected value of information approach. Med Care. 2008;46(5):542-8. [pmid: 18438203].
23 Stevenson MD, Scope A, Sutcliffe PA. The cost-effectiveness of group cognitive behavioral therapy compared with routine primary care for women with postnatal depression in the UK. Value in Health. 2010;13(5):580-4. [pmid: 20384978].
24 Detsky AS. Using cost-effectiveness analysis to improve the efficiency of allocating funds to clinical trials. Stat Med. 1990;9(1–2):173-84. [pmid: 2111932].
25 Forbes C, et al. A systematic review and economic evaluation of pegylated liposomal doxorubicin hydrochloride for ovarian cancer. Health Technology Assessment (Winchester, England). 2002;6(23):1-119.
26 Girling AJ, et al. Modeling payback from research into the efficacy of left-ventricular assist devices as destination therapy. International Journal of Technology Assessment in Health Care. 2007;23(2):269-77. [pmid: 17493314].
27 Townsend J, Buxton M, Harper G. Prioritisation of health technology assessment. The PATHS model: methods and case studies. Health Technology Assessment (Winchester, England). 2003;7(20):iii.
28 Willan AR, Pinto EM. The value of information and optimal clinical trial design. Statistics in Medicine. 2005;24(12):1791-1806. [pmid: 15806619].
29 Eckermann S, Willan AR. Expected value of information and decision making in HTA. Health Economics. 2007;16(2):195-209. [pmid: 16981193].
30 Willan A, Kowgier M. Determining optimal sample sizes for multi-stage randomized clinical trials using value of information methods. Clin Trials. 2008;5(4):289-300. [pmid: 18697843].
31 Eckermann S, Willan AR. Globally optimal trial design for local decision making. Health Economics. 2009;18(2):203-16. [pmid: 18435429].
32 Willan AR. Clinical decision making and the expected value of information. Clin Trials. 2007;4(3):279-85. [pmid: 17715257].
33 Barton GR, Briggs AH, Fenwick EA. Optimal cost-effectiveness decisions: the role of the cost-effectiveness acceptability curve (CEAC), the cost-effectiveness acceptability frontier (CEAF), and the expected value of perfection information (EVPI). Value in Health. 2008;11(5):886-97. [pmid: 18489513].
34 Fenwick E, et al. Assessing the impact of censoring of costs and effects on health-care decision-making: an example using the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Value in Health. 2008;11(3):365-75. [pmid: 17854433].
35 Groot Koerkamp B, et al. Value of information analysis used to determine the necessity of additional research: MR imaging in acute knee trauma as an example. Radiology. 2008;246(2):420. [pmid: 18227539].
36 Koerkamp BG, et al. Value of information analyses of economic randomized controlled trials: the treatment of intermittent claudication. Value in Health. 2010;13(2):242-50. [pmid: 19818058].
37 Omenn GS. Assessment of human cancer risk: challenges for alternative approaches. Toxicol Pathol. Suppl. 2001;29:5-12. [pmid: 11695561].
38 Oostenbrink JB, et al. Expected value of perfect information: an empirical example of reducing decision uncertainty by conducting additional research. Value in Health. 2008;11(7):1070-80. [pmid: 19602213].
39 Goeree R, et al. Health technology assessment and primary data collection for reducing uncertainty in decision making. J Am Coll Radiol. 2009;6(5):332-42. [pmid: 19394574].
40 Singh S, et al. Value of information of a clinical prediction rule: informing the efficient use of healthcare and health research resources. International Journal of Technology Assessment in Health Care. 2008;24(1):112-9. [pmid: 18218176].
41 Henriksson M, Lundgren F, Carlsson P. Informing the efficient use of health care and health care research resources - the case of screening for abdominal aortic aneurysm in Sweden. Health Economics. 2006;15(12):1311-22. [pmid: 16786498].
42 Martikainen JA, et al. Economic evaluation of temozolomide in the treatment of recurrent glioblastoma multiforme. Pharmacoeconomics. 2005;23(8):803-15. [pmid: 16097842].
43 Coyle D, Oakley J. Estimating the expected value of partial perfect information: a review of methods. Eur J Health Econ. 2008;9(3):251-9. [pmid: 17638032].
44 Iglesias CP, Claxton K. Comprehensive decision-analytic model and Bayesian value-of-information analysis: pentoxifylline in the treatment of chronic venous leg ulcers. Pharmacoeconomics. 2006;24(5):465-78. [pmid: 16706572].
45 Sculpher M, Claxton K. Establishing the cost-effectiveness of new pharmaceuticals under conditions of uncertainty--when is there sufficient evidence?. Value in Health. 2005;8(4):433-46. [pmid: 16091019].
46 Rao C, et al. Economic analysis of esophageal stenting for management of malignant dysphagia. Dis Esophagus. 2009;22(4):337-47. [pmid: 19207559].
47 Fleurence RL. Setting priorities for research: a practical application of ‘payback’ and expected value of information. Health Economics. 2007;16(12):1345-57. [pmid: 17328053].
48 Dong H, Coyle D, Buxton M. Value of information analysis for a new technology: computer-assisted total knee replacement. International Journal of Technology Assessment in Health Care. 2007;23(3):337-42. [pmid: 17579936].
49 Xie F, et al. Results of a model analysis to estimate cost utility and value of information for intravenous immunoglobulin in Canadian adults with chronic immune thrombocytopenic purpura. Clin Ther. 2009;31(5):1082-91. discussion 1066–8. [pmid: 19539109].
50 Groot Koerkamp B, et al. Uncertainty and patient heterogeneity in medical decision models. Med Decis Making. 2010;30(2):194-205. [pmid: 20190188].
51 Claxton K, et al. Bayesian value-of-information analysis. An application to a policy model of Alzheimer’s disease. International Journal of Technology Assessment in Health Care. 2001;17(1):38-55. [pmid: 11329844].
52 Hassan C, et al. Value-of-information analysis to guide future research in the management of the colorectal malignant polyp. Dis Colon Rectum. 2010;53(2):135-42. [pmid: 20087087].
53 Collins R, et al. A systematic review and economic model of the clinical effectiveness and cost-effectiveness of docetaxel in combination with prednisone or prednisolone for the treatment of hormone-refractory metastatic prostate cancer. Health Technology Assessment (Winchester, England). 2007;11(2):iii-iv. xv. xviii. 1. 179.
54 Fenwick E, et al. An iterative Bayesian approach to health technology assessment: application to a policy of preoperative optimization for patients undergoing major elective surgery. Medical Decision Making. 2006;26(5):480-96. [pmid: 16997926].
55 Oakley JE, et al. Simulation sample sizes for Monte Carlo partial EVPI calculations. Journal of Health Economics. 2010;29(3):468-77. [pmid: 20378190].
56 Claxton KP, Sculpher MJ. Using value of information analysis to prioritise health research: some lessons from recent UK experience. Pharmacoeconomics. 2006;24(11):1055-68. [pmid: 17067191].
57 Wilson E, et al. Cost-utility and value-of-information analysis of early versus delayed laparoscopic cholecystectomy for acute cholecystitis. Br J Surg. 2010;97(2):210-9. [pmid: 20035545].
58 Teerawattananon Y, Mugford M, Tangcharoensathien V. Economic evaluation of palliative management versus peritoneal dialysis and hemodialysis for end-stage renal disease: evidence for coverage decisions in Thailand. Value in Health. 2007;10(1):61-72. [pmid: 17261117].
59 McKenna C, et al. Enhanced external counterpulsation for the treatment of stable angina and heart failure: a systematic review and economic analysis. Health Technology Assessment (Winchester, England). 2009;13(24):iii-iv. ix. xi. 1. 90.
60 Grutters JP, et al. The cost-effectiveness of particle therapy in non-small cell lung cancer: exploring decision uncertainty and areas for future research. Cancer Treat Rev. 2010;36(6):468-76. [pmid: 20303217].
61 Fox M, et al. The clinical effectiveness and cost-effectiveness of cardiac resynchronisation (biventricular pacing) for heart failure: systematic review and economic model. Health Technology Assessment (Winchester, England). 2007;11(47):iii-iv. ix. 248.
62 Rodgers M, et al. Curative catheter ablation in atrial fibrillation and typical atrial flutter: systematic review and economic evaluation. Health Technology Assessment (Winchester, England). 2008;12(34):iii-iv. xi. xiii. 1. 198.
63 McKenna C, et al. A systematic review and economic evaluation of the clinical effectiveness and cost-effectiveness of aldosterone antagonists for postmyocardial infarction heart failure. Health Technology Assessment (Winchester, England). 2010;14(24):1-162.
64 Griebsch I, et al. Comparing the clinical and economic effects of clinical examination, pulse oximetry, and echocardiography in newborn screening for congenital heart defects: a probabilistic cost-effectiveness model and value of information analysis. International Journal of Technology Assessment in Health Care. 2007;23(2):192-204. [pmid: 17493305].
65 Karnon J. Planning the efficient allocation of research funds: an adapted application of a non-parametric Bayesian value of information analysis. Health Policy. 2001;61(3):329-47. [pmid: 12098524].
66 Rogowski W, et al. The effect of different treatment durations of clopidogrel in patients with non-ST-segment elevation acute coronary syndromes: a systematic review and value of information analysis. Health Technology Assessment (Winchester, England). 2009;13(31):iii-iv. ix. xi. 1. 77.
67 Basu A, Meltzer D. Value of information on preference heterogeneity and individualized care. Medical Decision Making. 2007;27(2):112-27. [pmid: 17409362].
68 Claxton K, et al. A pilot study on the use of decision theory and value of information analysis as part of the NHS Health Technology Assessment programme. Health Technology Assessment (Winchester, England). 2004;8(31):1-103. iii.
69 Colbourn T, et al. Prenatal screening and treatment strategies to prevent group B streptococcal and other bacterial infections in early infancy: cost-effectiveness and expected value of information analyses. Health Technology Assessment (Winchester, England). 2007;11(29):1-226. iii.
70 Colbourn TE, et al. Preventive strategies for group B streptococcal and other bacterial infections in early infancy: cost effectiveness and value of information analyses. BMJ. 2007;335(7621):655. [pmid: 17848402].
71 Bansback N, et al. Statin therapy in rheumatoid arthritis: a cost-effectiveness and value-of-information analysis. Pharmacoeconomics. 2009;27(1):25-37. [pmid: 19178122].
72 Galani C, et al. Uncertainty in decision-making: value of additional information in the cost-effectiveness of lifestyle intervention in overweight and obese people. Value in Health. 2008;11(3):424-34. [pmid: 18179675].
73 Rojnik K, Naversnik K. Gaussian process metamodeling in Bayesian value of information analysis: a case of the complex health economic model for breast cancer screening. Value in Health. 2008;11(2):240-50. [pmid: 18380636].
74 Hassan C, et al. Value-of-information analysis to guide future research in colorectal cancer screening. Radiology. 2009;253(3):745-52. [pmid: 19789242].
75 Peck SC, Kavet R. Research strategies for magnetic fields and cancer. Risk Analysis. 2005;25(1):179-88. [pmid: 15787767].
76 Wailoo AJ, et al. Cost-effectiveness and value of information analyses of neuraminidase inhibitors for the treatment of influenza. Value in Health. 2008;11(2):160-71. [pmid: 18380629].
77 Black C, et al. The clinical effectiveness of glucosamine and chondroitin supplements in slowing or arresting progression of osteoarthritis of the knee: a systematic review and economic evaluation. Health Technology Assessment (Winchester, England). 2009;13(52):1-148.
78 Grutters JP, et al. Decision-Analytic Modeling to Assist Decision Making in Organizational Innovation: The Case of Shared Care in Hearing Aid Provision. Health Serv Res. 2008.
79 Speight PM, et al. The cost-effectiveness of screening for oral cancer in primary care. Health Technology Assessment (Winchester, England). 2006;10(14):1-144. iii. iv.
80 Bojke L, et al. Identifying research priorities: the value of information associated with repeat screening for age-related macular degeneration. Medical Decision Making. 2008;28(1):33-43. [pmid: 18263560].
81 Castelnuovo E, et al. The cost-effectiveness of testing for hepatitis C in former injecting drug users. Health Technology Assessment (Winchester, England). 2006;10(32):iii-iv.
82 Robinson M, et al. Cost-effectiveness of alternative strategies for the initial medical management of non-ST elevation acute coronary syndrome: systematic review and decision-analytical modelling. Health Technology Assessment (Winchester, England). 2005;9(27):iii-iv.
83 Philips Z, Claxton K, Palmer S. The half-life of truth: what are appropriate time horizons for research decisions?. Medical Decision Making. 2008;28(3):287-99. [pmid: 18448701].
84 Smith KJ, et al. Cost-effectiveness of alternative outpatient pelvic inflammatory disease treatment strategies. Sex Transm Dis. 2007;34(12):960-6. [pmid: 18077847].
85 Garside R, et al. Surveillance of Barrett’s oesophagus: exploring the uncertainty through systematic review, expert workshop and economic modelling. Health Technology Assessment (Winchester, England). 2006;10(8):1-142.
86 Smits M, et al. Minor head injury: CT-based strategies for management--a cost-effectiveness analysis. Radiology. 2010;254(2):532-40. [pmid: 20093524].
87 Hewitt C, et al. Methods to identify postnatal depression in primary care: an integrated evidence synthesis and value of information analysis. Health Technology Assessment (Winchester, England). 2009;13(36):1-145. 147. 230.
88 Kee F, et al. The value of positron emission tomography in patients with non-small cell lung cancer. Eur J Radiol. 2010;73(1):50-8. [pmid: 19084367].
89 Grant A, et al. The effectiveness and cost-effectiveness of minimal access surgery amongst people with gastrooesophageal reflux disease - a UK collaborative study. The REFLUX trial. Health Technology Assessment (Winchester, England). 2008;12(31):1-181. iii. iv.
90 Bojke L, Hornby E, Sculpher M. A comparison of the cost effectiveness of pharmacotherapy or surgery (laparoscopic fundoplication) in the treatment of GORD. Pharmacoeconomics. 2007;25(10):829-41. [pmid: 17887805].
91 Karnon J, Carlton J, et al. Informing disinvestment through cost-effectiveness modelling: is lack of data a surmountable barrier?. Appl Health Econ Health Policy. 2009;7(1):1-9. [pmid: 19558190].
92 Hunink MG. Decision making in the face of uncertainty and resource constraints: examples from trauma imaging. Radiology. 2005;235(2):375-83. [pmid: 15858081].
93 Noorani HZ, et al. Priority setting for health technology assessments: a systematic review of current practical approaches. International Journal of Technology Assessment in Health Care. 2007;23(3):310-5. [pmid: 17579932].
94 INAHTA. Global Networking for Effective Healthcare. http://inahta.episerverhotell.net/News-archive/Website-Launch/. Accessed: 2012 Feb 10.
95 AHRQ, Justification of Estimates for Appropriations Committees. Fiscal Year 2011, D. 2011.
96 Husereau D, Boucher M, Noorani H. Priority setting for health technology assessment at CADTH. International Journal of Technology Assessment in Health Care. 2010;26(3):341-7. [pmid: 20584365].
97 CADTH, C.A.f.D.a.T.i. Health. 2008–2009 Annual Report. 2010.
98 NICE, N.I.f.H.a.C. Excellence. Topic Selection Programme Process Manual. 2008.
99 NIHR, N.H.T.A. programme. Identifying and prioritising HTA research.
100 USPSTF. U.S. Preventive Services Task Force (USPSTF). Procedure Manual. Section 2: Topic Selection, Prioritization, and Updating. 2008. www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual2.htm. Accessed: 2012 Feb 10.
101 World Health Organization. WHO Guideline Review Committee, WHO Handbook for Guideline Development. Geneva. 2010.
102 Oxman AD, Schunemann HJ, Fretheim A. Improving the use of research evidence in guideline development: 2. Priority setting. Health Res Policy Syst. 2006;4:14. [pmid: 17134481].
103 Cochrane Priority-Setting Workshop. 16th Cochrane Colloquium: Evidence in the Era of Globalisation. 2008. Freiburg, Germany.
104 Oortwijn WJ, et al. Priority setting for health technology assessment in The Netherlands: principles and practice. Health Policy. 2002;62(3):227-42. [pmid: 12385849].
105 SIGN, S.I.G. Network. SIGN 50: A guideline developer’s handbook. 2008.
106 SBU. Selecting Topics. www.sbu.se/en/About-SBU/Selecting-topics/. Accessed: 2012 Feb 10.
107 Goeree R, et al. Health technology assessment and primary data collection for reducing uncertainty in decision making. J Am Coll Radiol. 2009;6(5):332-42. [pmid: 19394574].
108 Rico R, Asua J. The prioritization of evaluation topics of health - primary research (Structured abstract). The Cochrane Library Health Technology Assessment Database. 2008;(1).
109 Neumann PJ. Emerging lessons from the drug effectiveness review project. Health Aff (Millwood). 2006;25(4):W262-71. [pmid: 16757486].
110 McDonagh M. Drug Effectiveness Review Project (DERP): Systematic Review Methods and Procedures. 2010.
111 Noorani H. Personal Communication. Topic Identification (AHRQ Cancer Comparative Effectiveness Review).
112 Palmer AJ, et al. Validation of the CORE Diabetes Model against epidemiological and clinical studies. Curr Med Res Opin. Suppl 1. 2004;20:S27-40. [pmid: 15324514].
113 Palmer AJ, et al. The CORE Diabetes Model: Projecting long-term clinical outcomes, costs and cost-effectiveness of interventions in diabetes mellitus (types 1 and 2) to support clinical and reimbursement decision-making. Curr Med Res Opin. Suppl 1. 2004;20:S5-26. [pmid: 15324513].
114 The Diabetes Prevention Program: baseline characteristics of the randomized cohort. The Diabetes Prevention Program Research Group. Diabetes Care. 2000;23(11):1619-29. [pmid: 11092283].
115 AHRQ. EHC Scientific Resource Center Secure Website. 2011. Access permission required. www.kpchr.org/ehc/. Accessed: 2012 Feb 10.
116 National Institutes of Health. Consensus Development Conference Statement: Phenylketonuria: Screening and Management. October 16–18, 2000.
117 Hegge KA, Horning KK, et al. Sapropterin: a new therapeutic agent for phenylketonuria. Ann Pharmacother. Sep. 2009;43(9):1466-73. [pmid: 19654333].
118 Jacobsen L, Niggemann B, et al. Specific immunotherapy has long-term preventive effect of seasonal and perennial asthma: 10-year follow-up on the PAT study. Allergy. 2007;62(8):943-8. [pmid: 17620073].
119 Friedman BW, Kapoor A, et al. The relative efficacy of meperidine for the treatment of acute migraine: a meta-analysis of randomized controlled trials. Ann Emerg Med. 2008;52(6):705-13. [pmid: 18632186].
120 French JA, Pedley TA. Clinical practice. Initial management of epilepsy. N Engl J Med. 2008;359(2):166-76. [pmid: 18614784].
121 Keene DL. A systematic review of the use of the ketogenic diet in childhood epilepsy. Pediatr Neurol. 2006;35(1):1-5. [pmid: 16814077].
122 Mandel A, et al. Medical costs are reduced when children with intractable epilepsy are successfully treated with the ketogenic diet. J Am Diet Assoc. 2002;102(3):396-8. [pmid: 11902372].
123 Kossoff EH. International consensus statement on clinical implementation of the ketogenic diet: agreement, flexibility, and controversy. Epilepsia. Suppl 8. 2008;49:11-3. [pmid: 19049576].
124 Olfson M, Marcus SC. National trends in outpatient psychotherapy. Am J Psychiatry. 2010;167(12):1456-63. [pmid: 20686187].
125 Mojtabai R, Olfson M. National trends in psychotherapy by office-based psychiatrists. Arch Gen Psychiatry. 2008;65(8):962-70. [pmid: 18678801].
126 Institute of Medicine (U.S.). Committee on Comparative Effectiveness Research Prioritization., Initial national priorities for comparative effectiveness research. Washington, DC. National Academies Press. 2009;xxiii:227.
127 Gaede P, et al. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003;348(5):383-93. [pmid: 12556541].
128 Jones AP, et al. Understanding diabetes population dynamics through simulation modeling and experimentation. Am J Public Health. 2006;96(3):488-94. [pmid: 16449587].
129 A.D.A. Diabetes Statistics. http://www.diabetes.org/diabetes-basics/diabetes-statistics/2011. Accessed: 2012 Feb 10.
130 Simon KC, et al. Hypertension, hypercholesterolemia, diabetes, and risk of Parkinson disease. Neurology. 2007;69(17):1688-95. [pmid: 17761552].
131 Sowers JR, Epstein M, Frohlich ED. Diabetes, hypertension, and cardiovascular disease: an update. Hypertension. 2001;37(4):1053-9. [pmid: 11304502].
132 U.S. National Cancer Institute. Cancer Intervention and Surveillance Modeling Network (CISNET). http://cisnet.cancer.gov/. Accessed: 2012 Feb 10.
133 U.S. National Heart Lung and Blood Institute. NHLBI Working Group on Value of Information Modeling. [Executive Summary]. 2010. www.nhlbi.nih.gov/meetings/workshops/info-modeling.htm. Accessed: 2012 Feb 10.
134 A.D.A.. The Diabetes Control and Complications Trial (DCCT). Design and methodologic considerations for the feasibility phase. The DCCT Research Group. Diabetes. 1986;35(5):530-45. [pmid: 2869996].
135 Zhou H, et al. A computer simulation model of diabetes progression, quality of life, and cost. Diabetes Care. 2005;28(12):2856-63. [pmid: 16306545].
136 UK Prospective Diabetes Study (UKPDS). VIII. Study design, progress and performance. Diabetologia. 1991;34(12):877-90. [pmid: 1778353].
137 AHRQ. HCUPnet, Healthcare Cost and Utilization Project. http://hcupnet.ahrq.gov/. Accessed: 2012 Feb 10.
138 Quon BS, Gan WQ, Sin DD. Contemporary management of acute exacerbations of COPD: a systematic review and metaanalysis. Chest. 2008;133(3):756-66. [pmid: 18321904].
139 Cox CE, et al. Differences in one-year health outcomes and resource utilization by definition of prolonged mechanical ventilation: a prospective cohort study. Crit Care. 2007;11(1):R9. [pmid: 17244364].
140 Statistics, U.S.N.C.fH., National Vital Statistics Reports (NVSR), in U.S. Census Bureau, Statistical Abstract of the United States. 2011:78.
141 Stanford RH, Shen Y, McLaughlin T. Cost of Chronic Obstructive Pulmonary Disease in the Emergency Department and Hospital: An Analysis of Administrative Data from 218 US Hospitals. Treat Respir Med. 2006;5(5):343-9. [pmid: 16928147].
142 Keenan SP, et al. Noninvasive positive pressure ventilation in the setting of severe, acute exacerbations of chronic obstructive pulmonary disease: more effective and less expensive. Crit Care Med. 2000;28(6):2094-102. [pmid: 10890671].
143 Esteban A, Ferguson ND, et al. Evolution of mechanical ventilation in response to clinical research. Am J Respir Crit Care Med. Jan. 15. 2008;177(2):170-7. [pmid: 17962636].
144 Ram FSF, Picot J, et al. Non-invasive positive pressure ventilation for treatment of respiratory failure due to exacerbations of chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2004;(3):CD004104. [doi: 10.1002/14651858.CD004104.pub3].
145 OANDA. Historical Exchange Rates. 2011.
146 Labor, U.D.o. Bureau of Labor Statistics, CPI Inflation Calculator. http://www.bls.gov/data/inflation_calculator.htm. Accessed: 2012 Feb 10.
147 Bank, W. Data: United States. 2011. http://data.worldbank.org/country/united-states. Accessed: 2012 Feb 10.
148 Whitlock EP, Eder M. EHC Topic Selection: Potential Role of Value of Information Analyses. Agency for Healthcare Research and Quality, EPC Meeting. [presentation]. 2011.
149 Bojke L, et al. Eliciting distributions to populate decision analytic models. Value in Health. 2010;13(5):557-64. [pmid: 20345548].