# Introduction

Systematic reviews are an important and relatively inexpensive type of research to inform clinical decisionmaking and the development of clinical guidelines, coverage or payment policies, and investments in implementation.1–3 Through the rigorous review and synthesis or meta-analysis of existing evidence, these studies may also reveal heterogeneity in patients and treatment effects, and suggest further research that can fill gaps in evidence. Indeed, systematic reviews have been found to be highly valuable to decisionmaking bodies and research funding agencies such as the Agency for Healthcare Research and Quality’s (AHRQ’s) Evidence-based Practice Centers (EPCs) because of their potential to promptly address diverse clinical questions or research topics, such as the comparative effectiveness of particular treatments and approaches to healthcare delivery.4 Systematic reviews are generally less expensive than trials or other (observational) studies in which primary data on health interventions are collected, i.e., less than $300,000 for a review compared with multimillions for large-scale randomized controlled clinical trials. However, systematic reviews consume research capacity and are costly enough that not all possible systematic reviews can be performed. With limited funds available to perform systematic reviews, it is essential to have an approach to set priorities among possible reviews so that the benefits from research funding are maximized (e.g., in terms of population health).

Value of information (VOI) analysis has been proposed as a strategy to inform priorities that can improve the effectiveness of spending on health research, including systematic reviews. 5,6 In contrast with subjective methods and more objective approaches to research prioritization like the burden of disease, clinical variation and “payback from research”, VOI explicitly quantifies the improvement in population-level benefits that is expected from research about the outcomes of alternative health interventions. This involves both predicting which of the interventions under consideration is preferred for all possible research outcomes and determining the expected value of that preferred option compared with the alternatives. An estimate of the VOI for a given trial, observational study, systematic review, or a combination or series of studies, can be calculated at the population-level and be compared with the costs of research, and the potential value of other research activities. In effect, the value expected from spending on a particular research project can be directly compared with the value expected from other ways to use those resources to improve health care in order to inform research decisions.

VOI calculations typically involve the construction of a decision-analytic model of the disease and its treatment to fully characterize the uncertainty in the benefits of particular treatments or health interventions being studied. As such, these “full-modeling VOI” analyses can aid in prioritizing studies that address research topics that may only be partial determinants of specific clinical or health policy decisions, and in prospectively estimating the efficiency in the design of new research studies. However, executing these exercises is often complex, demanding large degrees of analytic effort and data. In effect, a full modeling approach to VOI is likely to have substantial costs, which include not only resources invested in constructing the model and generating data as input for the analysis, but also the opportunity costs associated with the time it takes to report the results of VOI and decide upon research. The costs of VOI may sometimes exceed those of the studies under consideration, particularly when these studies are lower cost research efforts such as systematic reviews.

As alternatives to typical full-modeling VOI, newer approaches to analyzing the VOI can be identified that are less burdensome. We refer to these approaches as “minimal modeling,” “maximal modeling”, and “conceptual” VOI. A “minimal modeling” approach to VOI can sometimes be applied when evidence is available on the uncertainty in comprehensive measures of outcomes (e.g., both quality-adjusted life-years [QALYs] and costs) that readily address the clinical or policy decision in question.7 With this approach, the direct replication or bootstrapping of these outcomes can provide population-level estimates of VOI. Maximal modeling VOI requires a single comprehensive model to simultaneously establish the value of studying multiple research topics or clinical questions clustering within or across clinical domains. This approach is more demanding than full modeling VOI but can be advantageous if multiple topics can be addressed because the costs of VOI per individual topic are minimized. A third option to minimize the burden of VOI is to use a conceptual approach to VOI before formally quantifying the value of information through modeling. “Conceptual VOI” is based on the observation that VOI is calculated as a function of multiplicative elements, which include the potential difference in benefits between the topics or interventions under study, the effect on uncertainty about these benefits through further research, the probability that new evidence is durable and gets implemented into practice, and the size of the affected patient population. If any of these conceptual elements of VOI are relatively small, it is unlikely that the overall value of research, including VOI modeling, will be large. These less complex, lower cost approaches to VOI suggest the potential for practical application in informing research priorities for systematic reviews and other studies that are too inexpensive to justify a costly prioritization exercise.

Because the resources needed to support VOI often come out of budgets that might otherwise be used to fund new research, investments in VOI analyses should be made only if they improve the overall effectiveness of spending on health research. This is a special concern when VOI methods are applied to prioritize lower cost studies like systematic reviews. The question raised by the funder of this study, AHRQ, concerned whether and how VOI could be valuably applied to prioritize systematic reviews. In considering how VOI might be applied, we sought to assess whether an algorithmic approach could be developed to systematize how to identify the conditions under which the efforts invested in performing a VOI analysis to inform research priorities are likely to be well spent, and what type of VOI analysis to perform. As part of this, such an algorithm would help to determine when a less complex and lower cost VOI approach could be a feasible alternative to a full modeling approach so as to increase the practical application of VOI in developing meaningful estimates of the value of research.

The purpose of this study is to explore whether and how VOI analysis might be effectively and efficiently used to inform priorities for systematic reviews. Specifically, we (1) review VOI methods and the approaches currently described in the literature and used in practice to inform priorities for systematic reviews; (2) describe an algorithm for selecting the most appropriate approach to VOI for a given clinical question; and (3) apply this algorithm to assess its potential utility in prioritizing topics nominated to AHRQ’s EPCs for systematic review.

The outline of this report is as follows. In the next section, we report our review of VOI methods in which we outline the principles of VOI and the information on conceptual VOI elements necessary to provide a full estimate of the population value of information that would result from conducting further research. In addition, that section defines and discusses in detail the full, minimal, and maximal modeling and conceptual approaches to performing VOI, and describes whether and how these VOI methods have been used to date to inform priorities for clinical research studies, with a focus on their use in prioritizing systematic reviews. Based on insights from the review of VOI methodology, we then present the theory section of the report in which we describe an algorithmic approach for systematizing the use of VOI in informing research priorities. In the following section, we describe the results of our efforts to use this algorithm to identify the most effective and efficient VOI methods in prioritizing systematic reviews topics nominated to AHRQ’s EPCs. This section also illustrates how conceptual VOI, maximal modeling and minimal modeling may be feasibly applied as alternatives to full modeling VOI using a series of clinically related applications. Finally, in the last section, the discussion section, we discuss the main findings of our study and its practical implications for the use of VOI analysis to set priorities for systematic reviews.

Our results confirm that the consideration of VOI principles and methods may have a useful role in the process of informing priorities for systematic reviews, and that the practical application of value of information analysis can be systematized by following an algorithm that guides the process of identifying effective and efficient approaches to performing VOI. As such, VOI complements other subjective and more objective approaches to prioritizing research activities because it can motivate decisionmaking bodies or research funding agencies such as AHRQ to explicate the criteria relevant for priority-setting. In particular, VOI may provide useful quantitative measures of the potential value of research spending, or be a useful framework to help decisionmakers organize information about the value of research, including that about the durability of research findings, which we found had often been neglected in prior work. In effect, the results of our study suggest the implementation of a two-stage process by which VOI can be used in current triage or prioritization of systematic review topics, in which (1) conceptual VOI is applied to identify systematic reviews with no or limited expected value without formally quantifying this through complex modeling exercises, and (2) practical applications of minimal modeling, maximal modeling and full modeling VOI are selected to calculate the relative population-level value in the other systematic reviews topics on the basis of which these can be ranked and prioritized. A future direction of research would be to evaluate whether VOI analysis and a possible two-stage process to its practical application would be perceived as useful by those involved in research prioritization, and to formally test whether adding VOI to the standard priority-setting process would change decisions about performing systematic reviews and whether the outcomes of reviews in which decisions changed are in fact more valuable according to the different stakeholders in health care and improve the outcomes of research spending.