# Discussion

## General Findings

In this study, we sought to assess whether a systematic approach to the use of VOI to inform priorities for systematic reviews could be developed with the potential to improve the effectiveness of research spending on systematic reviews. We found a growing body of literature applying VOI to inform research priorities, and identified 78 published VOI studies, among which full modeling of the disease and its treatment – rather than less complex and less expensive VOI approaches - is the dominant approach to analysis. Despite the availability of some lower cost approaches to VOI, however, we found that VOI has seldom been applied to inform priorities for systematic reviews. Our review of the priority-setting processes in 13 major U.S. and international organizations revealed that VOI or its elements are not explicitly quantified when performing and/or funding systematic reviews, though ideas implicit in VOI principles are commonly applied, with the exception of durability of evidence. We identified that the high costs, also in terms of complexity, data, expertise and time requirements, of the most common (full-modeling) approaches to VOI are generally unlikely to be worthwhile when prioritizing systematic reviews but that lower cost VOI methods may be worthwhile under some circumstances. To this end, we developed an algorithm that describes a multistage process for identifying the effective and efficient approaches to performing VOI in systematic reviews. From assessing the potential utility of this algorithmic approach in topics nominated to AHRQ’s EPCs, we found that conceptual VOI, maximal modeling, and minimal modeling may often offer lower cost alternatives to full modeling approaches to provide estimates of value of systematic reviews. In a series of clinically related empirical applications, we described how the use of these lower cost methods could minimize the burden to practical application of VOI and aid in setting priorities among all possible systematic reviews for which resources are limited.

## Information Requirements of Application of Algorithm to VOI

Our results suggest that the algorithm to systematizing the use of VOI when prioritizing systematic reviews can be applied with only limited information requirements. Indeed, in applying the algorithm in review topics nominated to AHRQ in 2009, we found that a great deal of information needed to populate the multistage process to deciding about VOI was already generated as part of the triage process undertaken by the AHRQ EPCs. That is, the population of patients whom may benefit from the review outcomes was typically specified, while the potential benefits and uncertainty reduction in treatment alternatives and health interventions are considered as part of the EHC Program selection criteria relating to the “appropriateness,” “importance,” and “impact” of potential review topics. In addition, AHRQ topic briefs provided data – albeit that this primarily concerned qualitative information – on variation in care and the potential for change in practice, the development of clinical guidelines and that of ongoing or recently completed research, which can address potential limits on the implementation and durability of systematic review findings. In effect, our review of prioritization processes showed that the conceptual elements that determine the value of evidence synthesis are considered by most organizations involved in systematic review activities, even though variation exists in how these information elements are operationalized and measured. Data collection on comprehensive measures for health outcomes, costs and/or net benefits of treatments or health interventions, and that on the prospects of future research may require additional literature searches, environmental scans or expert elicitation. Where this information is available, decisions about whether and how to analyze the value of information from performing systematic reviews readily follow from the algorithm.

## Applicability of Algorithm to Select VOI Approaches

Because the development of our algorithm is based on general principles of VOI, the use of this algorithm may aid in identifying effective and efficient approaches to estimate the value of research also in contexts other than that of systematic reviews where VOI is considered for informing research priorities. Generally, our algorithmic approach seems to be advantageous in low-cost research efforts where budget limitations urge some prioritization. Aside from systematic reviews, such efforts may involve surveys for the prevalence or incidence of particular diseases or clinical conditions, or small-scale pilot studies of treatments, behavioral or delivery interventions. When applying VOI in a context of high-cost studies or combinations or series of studies that require substantial funding, the algorithm may find its most useful application in considering information on the probability of implementation, durability of research evidence and other conceptual elements that determine the population value of research so as to ensure that studies only receive funding when these are indeed expected to produce value. Examples of high-cost studies in which a more systematized use of VOI could be useful pertain not only to costly randomized controlled clinical trials but also to observational studies of policy changes or large-scale social experiments in which patients are randomly assigned to different forms of coverage. Regardless of the costs of research, the application of the algorithm would guide a systematized use of VOI when time and resources, including data and expertise, to perform VOI are limited.

## Applicability of Approaches to Calculating VOI

Our reviews and the applications suggest several situations in which lower cost methods, that is, conceptual VOI, maximal modeling or minimal modeling, may substitute full modeling approaches in an overall strategy of VOI to inform research priorities, which may include the performance of systematic reviews.

In providing informative bounds on the value of research, conceptual VOI is most likely to be useful when there is evidence suggesting low values in any of the multiplicative elements that determine the population-level VOI. Such situations may occur when the clinical use or implementation of research outcomes is prevented due to barriers such as a lack of knowledge or resistance by clinicians and/or patients, or strict coverage or payment policies. Another example would be in the case of rare diseases for which the value from research is limited because of the small population of patients affected. Unless the value for any of the elements of VOI equals zero, there may be some uncertainty associated with the decisions to rule out value in specific research studies or systematic reviews. As noted earlier, however, the consideration of a conceptual approach to VOI seems prudent before investing in more complex modeling to formally quantify the value of information in a particular intervention or research topic.

Substantial investments necessary to construct single comprehensive ‘maximal’ models that can simultaneously address multiple questions of VOI are only valuable in situations where multiple uses of these models can be anticipated. This is typically the case in more complex or chronic diseases like diabetes or cardiovascular disease in which health outcomes and resources use could be affected by multiple clinical conditions and interventions. A maximal modeling approach would allow the costs of modeling for current topics to be minimized, and may facilitate rapid and low-cost assessment of VOI for future topics. In effect, it could be worthwhile investing in building an infrastructure or research network, perhaps based on those decision models already available in a clinical domain, to collect and analyze relevant information from research projects in which the performance of VOI may aid in identifying evidence gaps and efficient designs of new research or adaptive trials.

Minimal modeling can be used to estimate the value in research topics when comprehensive outcome measures on the treatments or health interventions under comparison are readily available from trials, observational studies or meta-analyses. One example would involve a study that follows patient cohorts over the course of a particular disease and its treatment until death and that records all outcomes, like survival, quality of life and/or costs, relevant to address the clinical or policy decision in question. Another is when a study measures comprehensive outcomes data, from a trial in which survival is similar between two arms after some point, but survival or quality of life up to that point might differ. As illustrated in the new application of a minimal modeling approach to VOI in acute respiratory failure and earlier analyses, direct replication or bootstrapping of these data to address the value of information can be easily implemented in software such as WinBUGS or Stata. 7 Alternatively, modeling can be minimized when a trial or data set is available that can require only modeling of survival or other limited modeling exercises (e.g., utility mapping or approximation of cost) to generate comprehensive measures of health outcomes, costs, or net benefit that would readily allow VOI calculations in research topics.

We found very limited conditions for the use of typical full modeling approaches to VOI for research prioritization. This is typically only the case when further research is potentially valuable but costly, and the analysis of uncertainty in the effects of treatment or interventions on outcomes need to be sufficiently accurate so that this can aid in identifying relevant evidence gaps and the efficient design of new studies. In most situations, the construction of a full model of a disease and treatment process for analyzing the value expected from low cost studies, including systematic reviews, is most likely too costly to outweigh the returns expected from prioritizing among possible research projects and performing the actual research.

## Limitations of VOI Approach to Research Prioritization

In practice, prioritizing research, including systematic reviews, is not simply a task of performing VOI and balancing VOI estimates against each other. One of the reasons is that decision makers and other stakeholders in the prioritization process often have divergent values and preferences related to health and health care, and these different perspectives may affect how decisions about research spending are made. For example, we found that some decisions about the priority of topics nominated to AHRQ EPCs for systematic review deviated from those decisions that would come from applying our algorithmic approach to VOI.148 Indeed, these deviations can be explained in part because, in practice, some criteria like the burden of disease, variation in care, or equity considerations sometimes receive more weight than others in prioritizing research. In addition, some review topics passed through the selection process at AHRQ with the intent to refine the scope of these topics or develop technical briefs without recommending systematic reviews. In formally quantifying the value of information as an unweighted product of a selection of elements, VOI may not fully recognize the importance of alternative perspectives on the role of formal approaches to valuing research may play within the larger context of research prioritization and health care decisionmaking. Thus, we propose that our algorithm be used as a complement to, rather than as a substitute for, the judgment of informed decision makers.

In addition to the perhaps more selective nature of VOI, other limitations of an overall strategy of VOI to prioritizing research studies and systematic reviews should be noted. First, VOI analyses may often have to be restricted to establishing upper bounds (e.g., EVPI or pEVPI) on the value of research because it is difficult to predict the potential information that could result from new research. This is especially true in systematic reviews in which evidence synthesis may lead to greater uncertainty about the benefits of treatments or health interventions than that was anticipated before performing the systematic review. Predicting the value of systematic reviews becomes even more difficult when these are set up to explore heterogeneity in outcomes and patient groups that may be important to reflect in clinical guidance, coverage or payment policies, and directing further research. Even though measures of perfect information can provide useful indications of which systematic reviews or research studies are potentially worthwhile, it is preferred to come up with some estimate of research outcomes that can be balanced against the costs of research so as to sufficiently inform prioritization decisions about research funding. As illustrated in our minimal modeling analysis of value of information, this prediction or distribution of outcomes of particular research may be based on assumptions for the notional additional sample of patients or perhaps expert elicitation.149 Finally, current VOI approach to valuing research projects is limited by the fact that it does not explicitly account for ongoing activities that seek to promote the implementation of research outcomes into clinical practice.11,12 These activities may comprise the development of clinical practice guidelines or implementation strategies like patient counseling, medical education or academic detailing of clinicians, and payment incentives or reminders. Aside from the effect that active implementation of research may have on clinical behavior or performance and thus on health outcomes and resource use, the costs of investing in such activities would have to be considered in developing meaningful estimates of the value of research.

## Future Directions of Research

### Incorporation of VOI in Priority-Setting Processes

Among its primary advantages, VOI motivates decision makers and others involved in the process of research prioritization to explicate criteria relevant for priority-setting, and to provide quantified measures for making decisions about research spending. The use of VOI may lend transparency and credibility to prioritization decisions, especially if it is used as a precursor to scrutinizing objective data on the value of health research and to further subjective discussion. As a result, VOI seems to complement current subjective and more objective approaches to prioritizing research studies and systematic reviews. In essence, the results of our study suggest the implementation of a two-stage process by which VOI is incorporated into current prioritization processes. At first, information on each of the conceptual elements of VOI is used to “rule out” conducting research on topics that are expected to have low conceptual value of information. In a second stage, practical quantitative VOI methods are employed to assess the relative value of research projects that can be used in the ranking of these projects. Such a two-stage approach to the use of VOI seems applicable in the triage process for systematic reviews currently undertaken by the AHRQs EPCs. To allow for a broad perspective in valuing research, the approach to VOI can thereby be extended to incorporate the heterogeneity and weighing of different aspects of priority setting. For example, consideration of rare but catastrophic events or equity considerations can be included by weighting the expected net benefits appropriately, for example by adjusting the measure of health benefit accordingly. The expected value of individualized care may be especially important in cases in which heterogeneity in clinical or economic consequences of particular treatments or interventions is a critical concern.67 In extending the use of VOI in prioritization research, this type of analysis could aid not only in generating new research topics that would follow from modeling exercises that are constructed to provide estimates of VOI, but also in valuing research on topics within existing topics. For example, value of information analysis could address the value of studying the effect of medication switching on outcomes in patients with schizophrenia so as to inform clinical decisionmaking about treatment algorithms in these types of patients.

### Standardization of VOI Calculations

Implementation of VOI in priority-setting practice would require standardizing population-level VOI analyses if these are to be used to compare research projects and make prioritization decisions. To this end, it is critical that VOI estimates reflect appropriate assumptions about key parameters, ranging from disease-specific ones for measuring health outcomes, costs and utilities to more general assumptions, such as the perspective and time horizon of analysis, discount rates, and the broad population of patients being considered. In addition, standardized methodology needs to be developed for assessing the probability of implementation and durability of research evidence. A useful method for this may be the use of expert elicitation. The potential for elicitation exercises may extend to predicting research outcomes and correlation in information across topics and studies, providing guidance on how to structure complex decision-analytic models or adjustor update existing ones, and the appropriate weighting of conceptual elements of VOI. Standardization and transparency in the reporting of VOI studies would allow policymakers and others to critically assess the potential relevance of VOI indications from other settings to addressing their own decisions.

### Evaluation of the Use of VOI for Prioritizing Health Research

Because resources invested in performing VOI may essentially be invested directly in resolving clinical questions or providing health care, it seems important to evaluate whether a systematized use of VOI in research prioritization processes is indeed valuable. One way to study this would be to assess whether that process is useful to decision makers and other stakeholders prioritizing systematic reviews and would lead them to make decisions about the priority of systematic review that are different from the decisions they would have made without information about VOI. The latter could be evaluated by taking a retrospective look at the differences between prioritization decisions made in practice and those decisions that would come from ranking based on VOI estimates, an example of this is given by the work prepared by Whitlock and Eder.148 Discrete choice experiments may also be useful for eliciting whether prioritization decisions change—albeit in “hypothetical” scenarios—with estimates of VOI being presented along with evidence on other decision criteria like burden of disease, and for different values of these different criteria. One approach to assess the usefulness of VOI would be to convey survey decision makers and others involved in research prioritization in order to obtain feedback on whether VOI aids in organizing evidence to inform priority setting, and perhaps in communicating decisions about the focus of research and priority of particular research projects to the general public. Perhaps most importantly, it should be evaluated whether a new approach to research prioritization in which VOI is considered changes decisions that produces systematic reviews and other research studies that are more valuable to stakeholders, particularly in terms of health outcomes and resource use. To empirically evaluate this, the use of VOI would need to be incorporated into current priority-setting processes and then the outcomes of those processes would need to be systematically analyzed.

## Conclusion

We conclude that consideration of VOI principles and methods may have a useful role in informing priorities for systematic reviews. VOI seems likely to be able to help decisionmakers and others involved in the priority-setting process to explicate criteria and provide quantified measures of expected value that can be used to prioritize systematic reviews. Since AHRQ and other decisionmaking bodies and research funding agencies are investing greater resources in generating topics to consider for systematic review and it is unclear whether resources to perform all possible systematic reviews will be available, approaches to research prioritization such as VOI seem likely to become increasingly important. A systematized use of VOI in which an algorithm guides the choice among conceptual VOI, maximal, minimal and full modeling would minimize the burden to the practical application of VOI and ensure maximum benefit from research spending in terms of population health.