# Application

This section describes our efforts to assess the potential utility of applying the algorithm we developed for identifying the effective and efficient use of VOI in informing priorities for systematic reviews. We apply the algorithm for a selection of topics nominated to the AHRQ EPCs for systematic review. We explore whether application of our algorithm suggest that conceptual VOI, maximal modeling, minimal, or full modeling VOI may be useful in prioritizing systematic reviews. We also illustrate the application of these approaches in a few selected topics to illustrate how each of the lower cost approaches to VOI might be applied. We find that the application of the algorithm may be useful in selecting the appropriate VOI methods to inform priorities for systematic reviews that reduce the burden of the practical application of VOI.

## Methods

To assess its potential utility of our proposed algorithm, we applied it to attempt to identify appropriate VOI methodology to inform priorities for topics nominated to the AHRQ EPCs for systematic review in 2009. Topics for possible systematic reviews are generated through a nomination process described by Whitlock et al.4, and are then narrowed through triage meetings. The topic nominations were extracted from the minutes of the topic triage meetings at AHRQ.115 We considered only those topics that were reported to meet AHRQ’s criteria for relevance to its research or programmatic domain as well as the information requirements for topic nomination. The algorithm was not applied for topics that were addressed in research or programmatic activities already undertaken by the AHRQ EPCs, and/or duplicated with other topics already discussed in triage meetings before 2009. For each topic with potential for review, we applied the multistage algorithm to choose among conceptual VOI, minimal modeling, maximal modeling or full modeling as the effective and efficient approach to VOI for identifying the priority of that specific review topic (Appendix G). To populate each of the stages of the algorithm, we used information from a variety of sources, including the minutes of the topic triage meetings, clinicaltrials.gov, Google Scholar and MEDLINE^®^/Pubmed.

In a series of pilot studies, we illustrate and discuss how the application of conceptual VOI, maximal modeling and minimal modeling can be useful substitutes for full modeling VOI in applying VOI to inform priorities for systematic reviews while recognizing the costs of VOI and minimizing those costs. The two examples of conceptual VOI address review topics relating to (1) administering ketogenic diet in epileptic children, and (2) structuring of practice in community-based psychiatric care. The use of a maximal modeling approach to VOI is discussed with respect to its potential application for simultaneously addressing multiple questions about the value of systematic reviews in topic nominations clustered in diabetes care. Minimal modeling VOI is applied to assess the value of information from updating a review of evidence on non-invasive versus invasive mechanical ventilation in acute respiratory failure. To demonstrate the application of full modeling VOI to inform priorities for systematic reviews, we refer to our review of VOI studies in the theory section of this report. This is because our analysis above suggests that a decision to fully model a disease and treatment process will generally be made primarily for the purpose of efficiently designing trials or other (observational) studies that are likely to be planned for the collection of additional primary data following the performance of a systematic review.

## Results

### Identification of Topics Nominated for Systematic Review

In 2009, 73 topics were nominated for systematic reviews to the AHRQ EPCs. Of these, 10 topics did not fit within the AHRQ’s EHC Program and/or failed to meet minimum information requirements for topic nomination. Another 11 topics were already addressed by existing research or programmatic activities. Eleven out of the remaining 52 topics were not considered for algorithm application because they were duplicates of earlier topics discussed. In total, 41 topics were identified as having potential for review, and were used to evaluate the potential utility of our algorithm in selecting VOI methods for prioritizing systematic reviews. These topics primarily covered questions about the comparative effectiveness of treatments or health interventions, and included a wide range of clinical domains, including pain management, cardiovascular diseases and cancer. The set of topics seemed broadly representative of topics typically nominated to the AHRQ EPCs for systematic review.

### Approaches to VOI in Prioritizing Systematic Reviews

As shown in Figure 4, each of the different approaches to VOI (i.e., conceptual VOI, maximal modeling, minimal modeling, and full modeling) was judged as having some applicability within an overall strategy of applying VOI to inform priorities among the topics nominated to AHRQ for systematic review in 2009.

Figure 4 Application of algorithm for identifying the effective and efficient approaches to VOI to inform priorities for topics nominated to the AHRQ EPCs for systematic review in 2009

^1^ Topics: 1) Electroconvulsive Therapy in Elderly; 2) Specialized Wheelchairs for Patients; 3) Upright MRI; 4) Vagus Nerve Simulation for Depression; 5) Family Involvement in Hospital Discharge Planning; 6) Treatment of Glaucoma; 7) Home Oxygen Therapy; 8) Prevention and Early Detection of Skin Cancer; 9) Treatment of Neovascular Age-Related Macular Degeneration; 10) Herbal Therapies for Cholesterol Reduction; 11) Ketogenic Diet for Epileptic Children; 12) Dietary Supplements in Elderly taking Cardiovascular Drugs; 13) DVT Prophylaxis for Special Populations; 14) Complementary and Alternative Medicine for Benign Prostatic Hyperplasia; 15) Hormone Therapy for Treatment of Menopausal Symptoms; 16) School-Based vs Outpatient Speech Therapy for Children; 17) Multimodal Pain Management in Adults; 18) Anesthesia in Infants; 19) Phenylalaninerestricted Diet for Phenylketonuria;20) Surgical Treatment of Chronic Pelvic Pain; 21) Practice Structuring in Community-Based Psychiatric Care.

^2^ Topics: 1) Occupational and Physical Therapy; 2) Antipsychotics for ADHD; 3) Noninvasive Positive Pressure Ventilation for Acute Respiratory Failure; 4) Allergen-Specific Immunotherapy; 5) Acute Migraine Treatment in Emergency Settings; 6) Prophylactic Treatment of Migraine with Alzheimer’s Medication.

^3^ Topics: 1) H2RAs and PPIs for GERD; 2) Self-Measured Blood Pressure Monitoring; 3) Pharmacologic Therapies for Management of Crohn’s Disease; 4) Prevention of Venous Thromboembolism in Orthopedic Surgery; 5) Biologics vs Conventional Systemic Treatments for Moderate and Severe Psoriasis; 6) Effectiveness of Nurse Case Managers; 7) Procalcitonin-guided Therapy for Sepsis; 8) Physician Outreach via Email and Internet Networking

^4^ Topic: 1) Antinuclear Autoantibody and Rheumatoid Factor Testing.

^5^ Topics: 1) Urinary Incontinence; 2) Blood Glucose Control; 3) Noninvasive Technologies for Diagnosis of CAD in Women; 4) Mental Health Support for Juvenile (Type 1) Diabetes Mellitus; 5) Natriuretic Peptide Measurement in Heart Failure;

ADHD: attention deficit hyperactivity disorder; AHRQ: Agency for Healthcare Research and Quality; CAD: coronary artery disease; DVT: deep vein thrombosis; EPCs: Evidence-based Practice Centers; GERD: gastroesophageal reflux disease; H2RAs: histamine receptor antagonists; MRI: [underlined: magnetic resonance imaging]; PPIs: proton pump inhibitors; VOI: value of information.

Figure 4 is a flowchart demonstrating the results of the application of the algorithm for identifying the effective and efficient approaches to VOI to inform priorities for topics nominated to the AHRQ EPCs for systematic review in 2009. It begins with the 41 potential topics that were nominated for systematic review, and ends by categorizing 21 (51%) of these topics as “no further VOI” needed based on low conceptual VOI, 5 (12%) of these topics as appropriate for maximal modeling, 6 (15%) of these topics as appropriate for minimal modeling, 0 (0%) of these topics as “no further VOI” based on the fact that additional collection of primary data is not expected to be valuable, 8 (20%) of these topics as appropriate for full modeling, and 1 (2%) of these topics as “no further VOI” based on the fact that additional collection of primary data is not expected to be costly. This figure is described in great detail under the section “Application, Results, Approaches to VOI in Prioritizing Systematic Reviews” as follows: “As shown in Figure 4, each of the different approaches to VOI (i.e., conceptual VOI, maximal modeling, minimal modeling, and full modeling) was judged as having some applicability within an overall strategy of applying VOI to inform priorities among the topics nominated to AHRQ for systematic review in 2009. By using information on the elements that determine the population-level VOI of a systematic review, we found that a conceptual approach to VOI suggested the informative value in formally quantifying VOI through modeling to be low in 21 (51%) nominated review topics. In most of these topics (86% of 21 topics), the review and synthesis of evidence was not expected to produce any valuable insights because of the lack of trials or other (observational) studies comparing treatment or health intervention options under consideration. Data or information to describe the potential limits in the implementation and durability of systematic review evidence were more difficult to find, although some variation in clinical care and coverage or payment policies may frequently be anticipated. One (5%) topic, the use of supplementary pharmacological therapy in phenylketonuria, was identified in which a very small incident population of about 2000 patients per year and the lack of any primary research suggesting long-term improvement in quality of life from reduced phenylalanine concentrations and dietary phenylalanine restrictions from supplementary pharmacological therapy (e.g., sapropterin dihydrochloride) has not been demonstrated in any primary research study yet [115,116], argued for lower priority in spending on a systematic review compared with the other topics considered. In the 19 (49% of 41 topics) systematic review topics in which modeling could not be excluded because of low conceptual VOI, we found that maximal modeling or minimal modeling approaches to VOI frequently offered lower-cost alternatives to typical full modeling VOI when informing priorities among possible systematic reviews. The application of maximal models is a potentially valuable approach to VOI in 5 (12%) systematic review topics, as these topics were found to cluster with other review topics within or across diverse clinical domains. These clusters of topics concerned patient management in urinary incontinence, coronary artery disease, heart failure, and diabetes (2x). In addition to the clustering of multiple topics for systematic reviews, a maximal modeling approach to VOI was also found to be feasible in a single review topic or intervention for which multiple uses could be anticipated. One of example this related to the measurement of natriuretic peptides that comprised a single topic with potential value in the management of congestive heart failure for both the diagnosis of patients and control in treatment. As such, a single comprehensive model could be constructed with which to simultaneously assess the value in the reviews of evidence on the alternative uses of peptide measurement. In almost one-third (30%) of the systematic review topics, comprehensive outcome measures were found to be readily available, and minimal modeling could be used to provide estimates of VOI in these topics. For example, the value of performing a review on the comparative effectiveness of allergen-specific immunotherapy as supplement to usual care could be assessed using the 10-year follow up data on asthma incidence that was available from the Preventive Allergy Treatment study [117]. A similar approach could be applied using the results from an existing meta-analysis reporting pooled odds ratios for headache relief from acute migraine treatment (non-opiods versus opiods) in emergency settings [118]. Direct replication of these data or perhaps limited modeling exercises in which asthma incidence data or headache relief scores are related to quality of life and/or life expectancy could facilitate low-cost and rapid assessments of VOI in performing systematic reviews, or updates of reviews, on these topics that could be of use in priority setting. Full modeling VOI was found to be potentially valuable in 8 (20%) of the 41 potential review topics nominated to AHRQ EPCs. In these topics, the planning of further research was anticipated to be most likely, and the trials or (observational) studies for additional data collection were expected to be both valuable and costly. As a result, the construction of full models of the disease and treatment processes in these topics was thought to aid in identifying most relevant evidence gaps and establishing efficient research designs. The formal quantification of VOI based on a full modeling approach would not be an efficient spending of research funds in antinuclear autoantibody and rheumatoid factor testing in children with musculoskeletal pain. The review and synthesis of existing evidence on the prevalence of musculoskeletal pain from rheumatic causes is likely to reveal useful information to guide diagnostic testing in children in primary care settings and may suggest proceeding with further collection of prevalence data. However, since many practice registries and ongoing studies exist in this area, performing such analysis of prevalence is likely to be too inexpensive to justify using a full modeling VOI approach.”

By using information on the elements that determine the population-level VOI of a systematic review, we found that a conceptual approach to VOI suggested the informative value in formally quantifying VOI through modeling to be low in 21 (51%) nominated review topics. In most of these topics (86% of 21 topics), the review and synthesis of evidence was not expected to produce any valuable insights because of the lack of trials or other (observational) studies comparing treatment or health intervention options under consideration. Data or information to describe the potential limits in the implementation and durability of systematic review evidence were more difficult to find, although some variation in clinical care and coverage or payment policies may frequently be anticipated. One (5%) topic, the use of supplementary pharmacological therapy in phenylketonuria, was identified in which a very small incident population of about 2000 patients per year and the lack of any primary research suggesting long-term improvement in quality of life from reduced phenylalanine concentrations and dietary phenylalanine restrictions from supplementary pharmacological therapy (e.g., sapropterin dihydrochloride) has not been demonstrated in any primary research study yet,116,117 argued for lower priority in spending on a systematic review compared with the other topics considered.

In the 19 (49% of 41 topics) systematic review topics in which modeling could not be excluded because of low conceptual VOI, we found that maximal modeling or minimal modeling approaches to VOI frequently offered lower cost alternatives to typical full modeling VOI when informing priorities among possible systematic reviews.

The application of maximal models is a potentially valuable approach to VOI in 5 (12%) systematic review topics, as these topics were found to cluster with other review topics within or across diverse clinical domains. These clusters of topics concerned patient management in urinary incontinence, coronary artery disease, heart failure, and diabetes (2x). In addition to the clustering of multiple topics for systematic reviews, a maximal modeling approach to VOI was also found to be feasible in a single review topic or intervention for which multiple uses could be anticipated. One of example this related to the measurement of natriuretic peptides that comprised a single topic with potential value in the management of congestive heart failure for both the diagnosis of patients and control in treatment. As such, a single comprehensive model could be constructed with which to simultaneously assess the value in the reviews of evidence on the alternative uses of peptide measurement.

In almost one-third (30%) of the systematic review topics, comprehensive outcome measures were found to be readily available, and minimal modeling could be used to provide estimates of VOI in these topics. For example, the value of performing a review on the comparative effectiveness of allergen-specific immunotherapy as supplement to usual care could be assessed using the 10-year follow up data on asthma incidence that was available from the Preventive Allergy Treatment study.118 A similar approach could be applied using the results from an existing meta-analysis reporting pooled odds ratios for headache relief from acute migraine treatment (non-opiods versus opiods) in emergency settings.119 Direct replication of these data or perhaps limited modeling exercises in which asthma incidence data or headache relief scores are related to quality of life and/or life expectancy could facilitate low-cost and rapid assessments of VOI in performing systematic reviews, or updates of reviews, on these topics that could be of use in priority setting.

Full modeling VOI was found to be potentially valuable in 8 (20%) of the 41 potential review topics nominated to AHRQ EPCs. In these topics, the planning of further research was anticipated to be most likely, and the trials or (observational) studies for additional data collection were expected to be both valuable and costly. As a result, the construction of full models of the disease and treatment processes in these topics was thought to aid in identifying most relevant evidence gaps and establishing efficient research designs. The formal quantification of VOI based on a full modeling approach would not be an efficient spending of research funds in antinuclear autoantibody and rheumatoid factor testing in children with musculoskeletal pain. The review and synthesis of existing evidence on the prevalence of musculoskeletal pain from rheumatic causes is likely to reveal useful information to guide diagnostic testing in children in primary care settings and may suggest proceeding with further collection of prevalence data. However, since many practice registries and ongoing studies exist in this area, performing such analysis of prevalence is likely to be too inexpensive to justify using a full modeling VOI approach.

### Applications of Conceptual VOI

To demonstrate the value of a conceptual approach to VOI, we discuss two nominated systematic review topics for which information on different elements of population-level VOI (i.e., uncertainty reduction versus the implementation and durability of evidence) provide bounds on the value expected from performing a systematic review. We have selected: (1) ketogenic diet for epileptic children, and (2) structuring of practice in community-based psychiatric care as examples in which zero or low conceptual VOI suggest low priority without formally quantifying the value of reviews in the topics.

#### Limited Reduction in Uncertainty: Ketogenic Diet in Children with Epilepsy

One condition under which a conceptual approach to VOI can provide informative bounds on the value of a systematic review is when there is no benefit expected in this because there is no available comparative effectiveness evidence to synthesize. This seems to be the case for the review of evidence on ketogenic diet in children with intractable or refractory epilepsy. In the U.S., about 2.1 million children are diagnosed with epilepsy each year.120 In 55 percent of these patients, pharmacotherapy is not effective and seizures persist. A subset of these patients may benefit from ketogenic diet with increased seizure control, reduced adverse effects, and the containment of medical costs.121,122 While the population expected benefits from review of evidence is sizable, there is limited guidance on how to administer ketogenic diet (e.g., dosing, duration and vitamin supplements) and considerable variation exists in clinical care.123 Perhaps because of this, we found no trial comparing ketogenic diet against anti-epileptic drugs for refractory or intractable epilepsy. The long-term adverse effects of the dietary treatments are also typically unknown. Even if trials or other (observational) studies did exist that were sufficiently similar, the rapid emergence of newer antiepileptic drugs with improved efficacy and convenience would reduce the durability of the value of any findings from a review.121 We found that the potential for reducing uncertainty in benefits of treatment through performing a systematic review on ketogenic diet is likely very low because of the lack of comparability in existing studies. This issue arose frequently in many other review topic nominations.

#### Low Probability of Implementation and Limited Durability of Information: Practice Structuring in Community-Based Psychiatric Care

Implementation issues and a limited durability of review findings from systematic reviews can bound the value in performing VOI to prioritize among possible review topics. As an example of this, we found that a conceptual approach to VOI suggests a low value in the review of evidence on the comparative effectiveness of practices structuring in community-based based psychiatric care, in which 30- or 45-minute checks complemented with traditional psychotherapy are considered as alternatives to standard 15-minute medication checks. This topic has a large relevant population, with 25 million independent visits to psychiatrists in 2006, and 3.18 percent of the U.S. population using outpatient therapy as of 2007.^124,125^ Many psychiatric patients with prescriptions interact with their physicians only during monthly 15-minute medication checks. This has become standard practice due to coverage or payment policies by Medicaid and insurance companies. We found no research, no trial, or no observational study in which the comparative effectiveness of alternative ways of structuring psychiatric practice is evaluated. The lack of head-to-head comparisons due to differences in indication, condition, and severity makes it unlikely that conducting a systematic review is going to impact practice. Moreover, the research agenda on psychiatric services is likely to be heavily influenced by the IOM meeting on Initial National Priorities for Comparative Effectiveness Research,126 which makes the findings, if any, of a systematic review on this topic less likely to be durable. The apparent barriers to changing standard practice and the limited durability of review evidence suggest that this topic will have a low VOI. Even though a system review may still have potential value in identifying evidence gaps and priorities for future research in this area, it is not clear that a systematic review is per se needed given the ease with which it is possible to determine that comparative effectiveness evidence on practices structuring for psychiatric care is lacking.

### Application of a Maximal Modeling Approach to VOI: Multiple Topics Clustering in Diabetes Care

Some of the best examples of maximal modeling as an effective and efficient approach to VOI are likely to be in management of common chronic diseases or clinical conditions, such as diabetes. Diabetes-related research, which may include systematic reviews that synthesize evidence from the many studies in this domain, is expected to be highly valuable because of the major health and costs burden that diabetes imposes on the U.S. population.127,128 Almost 26 million people suffer from diabetes, of which 90–95 percent have (adult-onset) diabetes type 2, while the others suffer from insulin-dependent diabetes type 1.^129^ Patient management of either form of diabetes is typically complex, using multiple assessment tools and interventions. These can include screening and preventive measures in different at-risk groups or the whole population, diagnostics tools such as oral glucose tolerance tests, fasting blood glucose tests or glycosylated hemoglobin, and insulin therapy or medication medical or dietary or lifestyle interventions. Diabetes is highly associated with hypertension and hypercholesterolemia, and obesity, making interventions to address these comorbid factors critical to the management of diabetes.130,131 Between 2008 and 2010, the AHRQ EPCs received 10 nominations for systematic review on 7 separate topics related to diabetes. Of these, 2 topics pertained to diabetes type 1^9^, 4 topics to diabetes type 2^10^, and 1 topic pertained to both types of diabetes^11^. With numerous nominations of topics that can be clustered within the single domain of diabetes care, this suggest the consideration of constructing a maximal model that describes the relationship between these topics and interventions and that can be used to simultaneously assess the potential value of multiple systematic reviews. Of note, both the National Cancer Institute and the National Heart Lung and Blood Institute have recently explored the use of maximal modeling approaches to VOI as a means to prioritize research in the major disease areas of interest to them.132,133

9 Topics: Mental Health Support for Juvenile (Type 1) Diabetes Mellitus; Daily Insulin Injections or Insulin Pump Therapy with and without Continuous Glucose monitoring.

10 Topics: Tight Management vs. Loose Control of Blood Glucose for Hospitalized Patients with Type II Diabetes; Comparative Effectiveness of Short- and Long-Acting Insulin and Insulin Analogs for Adults with Type 2 Diabetes Mellitus; Harms and Benefits of Different Possible Combinations of Medications for the Treatment of Dyslipidemia in Adults with Type 2 Diabetes; Therapies for Impaired Glucose Tolerance to Prevent Progression to Type 2 Diabetes.

11 Topic: Point-of-Care Testing for Glycated Hemoglobin.

Diabetes is a particularly suitable disease candidate for maximal modeling because a number of models have already been developed and validated, and could potentially be used to facilitate VOI analysis. For example, the CORE Diabetes Model could be of use in simultaneously addressing VOI in systematic review topics that relate to both diabetes type 1 and type 2.^112,113^ This model is based on data from the Diabetes Control and Complications Trial, and simulates the long term health and economic consequences of treatments and interventions in diabetes types 1 and 2 to support clinical and policy decisionmaking, with the option to consider various diabetes complications like stroke, hypoglycemia, and end stage renal disease. 134 For diabetes type 2, we also refer to the CDC-RTI Cost-Effectiveness model and the University of Michigan model. This first model could potentially be used to analyze VOI in both preventive measures and treatment interventions in diabetes type 2, and includes features to simulate diabetes prescreening and the impact of prediabetes.114 The second model might aid in predicting the onset and progression of type 2 diabetes, and has additional features that would allow to simultaneously assess the value that can expected from studying the effect of screening, diagnostic tools, and treatment compliance on outcomes.135 When relying on one or more of the existing diabetes models to address multiple questions on VOI, it might be important to adapt these models to the specific context in which decisions are made about the priority of systematic reviews on various topics related to diabetes type 1 and type 2. For example, both the CDC-RTI and the University of Michigan model are populated with data from the United Kingdom Prospective Diabetes Study136 and therefore would require adjustment or updating to provide estimates of VOI that reflect the U.S. population of diabetes patients.

### Application of a Minimal Modeling Approach to VOI

To assess the potential of minimal modeling approaches to provide information on the value expected from performing systematic reviews, we discuss one new clinical empirical application that requires “no modeling.” In this application, we studied the comparative effectiveness of noninvasive positive pressure ventilation versus standard therapy in acute respiratory failure. We chose this application as an example in which data on comprehensive outcome measures, i.e., both in-hospital patient mortality and costs, are available that allow direct replication of these data to estimate the population-level VOI of updating the review of evidence on this topic.

#### Use of Available Data on Comprehensive Outcome Measures: Noninvasive Positive Pressure Ventilation in Acute Respiratory Failure

In the U.S., more than 850,000 patients are admitted to the hospital with acute respiratory failure each year.137 Next to acute cardiogenic pulmonary edema and other indications, these admissions most frequently concern exacerbations of chronic obstructive pulmonary disease (COPD). Standard medical therapy in these patients includes supplemental oxygen, bronchodilators, antibiotics, corticosteroids, and diuretics. A recent meta-analysis, pooling data from 11 studies, found that noninvasive positive pressure ventilation (NPPV), as supplement to initial therapy, reduce in-hospital patient mortality (relative risk: 0.45; 95% confidence interval [CI], 0.30–0.60) and length of hospital stay (difference: −1.94 days; 95% CI: 3.87–0.01) during acute exacerbations of COPD.138 Because the benefits of NPPV are not known with certainty and additional costs (+$7,012) are associated with administering NPPV in patients, the expense of masks and oxygen supplementation, the training of clinical staff, and the acquisition of ventilators and monitoring systems, further research could potentially aid in informing treatment choice in acute respiratory failure.

Given this background, we sought to examine whether a minimal modeling approach to VOI could provide useful data on the priority for an update of the review of evidence on the comparative effectiveness of NPPV versus standard therapy for acute respiratory failure in patients with COPD.

To estimate population-level VOI, we replicated summary data available from Quon et al.138 on the relative risk of in-hospital mortality and difference in the length of hospital stay through simulation in WinBUGS, assuming independent, (log)normal distributions for the both (Table 7; Appendix H). The population expected value of updating a review on acute respiratory treatment (pEVI) was established as the difference between the population expected value of perfect information given meta-analysis data (pEVPI_prior_) and that with predicted outcomes for additional patient samples that could come from the review update (pEVPI_post_). To calculate net benefit of treatment alternatives on a per patient basis, we accounted for the gain in life-years assuming a baseline mortality of 25% and an age-adjusted life expectancy of 4.4 years for patients admitted to hospitals with respiratory failure and whom require ventilation (mean age: 67 years), and subtracted the difference in costs of hospital stay and treatment from the product of life-years saved and the willingness-to-pay or cost-effectiveness threshold.138–140 For all model evaluations of VOI to achieve convergence, we discarded initial 50,000 ‘burn-in’ sample iterations, and based inferences on further runs of 50,000 iterations.

Table 7 Details of application for minimal modeling approach to VOI in acute respiratory failure

Application | Noninvasive Positive Pressure Ventilation Versus Standard Therapy
Minimal Modeling | Direct replication through parametric simulation of data in WinBUGS [Appendix H]
Setting | U.S.
Perspective | Societal
Data | Baseline in-hospital mortality rate in patients with respiratory failure: 25% [138] Costs of hospital stay: $600 per day [141] Administration Costs of NPPV: $17,711^†^ [142] Costs of standard therapy: $10,699^†^ [142] Life-expectancy patients surviving respiratory failure: 4.4 years^§^ Implementation of NPPV in hospitals: 11% [143] Non-toleration to NPPV by patients: 13% [144] Durability of information: 5 years [assumption] Evidence from Available Meta-Analysis for Prior Analysis [138]; - Relative risk of in-hospital mortality: 0.45 (95% CI: 0.30, 0.60; sample size: 940); - Difference in length of hospital stay: −1.94 days (95% CI: −0.01, −3.87; sample size, 956); Assumptions regarding Additional Review Findings for Posterior Analysis; - Additional samples of patients: 500, 1000, 2000, 3000, 4000, 5000, 6000 patients
Incidence | 850,000 hospital admissions per year [137]
Time horizon | 5 years (durability = 1,0 for all years over this time horizon)
Discounting | 3%
Cost-effectiveness threshold | λ: 0-$100,000 per life-year saved
VOI results | Prior Analysis; - pEVPI_prior_= $149,30 million^*^; - Pr(Net Benefit > 0) = 0.54^*^; Posterior Analysis; - pEVPI_post_ = $85,7 million^*^; - pEVI = $63,6 million^*^; - Population-level returns of systematic review = $63,3 million^*^, with expected costs of systematic review = $300,000; ^*^λ: $15,000 per life-year saved (~ICER)

CI: confidence interval; ICER: incremental cost-effectiveness ratio of NPPV compared with standard therapy; NPPV: Noninvasive Positive-Pressure Ventilation; pEVI: population expected value of information from review update with predicted outcomes for additional sample of 500 patients [138]; pEVPI_postr_: population expected value of perfect information with (posterior) predicted outcomes for review update with additional sample of 500 patients; pEVPI_prior_: population expected value of perfect information prior to updating review, based on available meta-analysis; Pr(Net Benefit > 0): probability that NPPV is net beneficial (or cost-effective) compared with standard therapy; VOI: value of information; λ: cost-effectiveness threshold.

† 2009 $ costs were calculated by adjusting cost indexations from Keenan et al. [142] for historical currency exchange rates [145] (i.e., average daily over period 01/01/year of study and 12/31/year of study), and consumer price indexations [146,147].

§ Life expectancy of patients with respiratory failure was calculated as the weighted average over an approximate 75% of patients within 65–74 age group die within 100 days [139], and 25% of patients with an average of 16.8 years of life remaining [140].

The analysis of VOI was performed from a societal perspective, in which the opportunity costs for labor is not expected to differ between NPPV and standard treatment because of the pensionable age of patients with hospital admissions for acute exacerbations of COPD. In establishing the population level value of updating the earlier meta-analysis, only a limited proportion of patients with acute exacerbations is expected to receive NPPV in practice (i.e., probability of implementation = 11%), while 13 percent of patients is expected to be intolerant to non-invasive ventilation because of claustrophobia or frequent productive cough. In addition, we assumed the information from the potential review update to be durable over a time horizon of 5 years, and used a discount rate of 3 percent. The results of our analysis are represented in an acceptability curve and expected VOI curves over a range of threshold values for cost-effectiveness on the basis of which a treatment decision could be made.

As shown in Figure 5, the population expected VOI suggests that performing a systematic review to provide more precise estimates on the net benefit of NPPV compared with standard treatment in exacerbations of COPD is unlikely to be valuable over a wide range of threshold values for cost-effectiveness. Specifically, the pEVI is not expected to exceed the expected costs of $300,000 for a review update for a cost-effectiveness threshold less than $8000 or over $26,000 per life-year saved. For a more common threshold of $50,000 per life-year saved, the supplementary use of NPPV in acute respiratory failure is recommended without further research to inform this treatment decision. This is because of the statistically significant effect of treatment alternatives on in-hospital mortality-risk and hospital stay from meta-analysis.138 The upper bounds on the value that can be expected from further research (pEVPI_prior_) broadly range from $554,500 to $149.30 million for threshold values around $15,000/life-year for which the decision about optimal treatment of acute respiratory would change. Essentially, these VOI calculations are not very different from some standardized VOI estimates available, ranging from $2 million to $125 billion, for other studies.7 The population value of updating a review on acute respiratory treatment (pEVI) varies considerably with the additional sample of patients that may be found. This value decreases with larger sample sizes because it then becomes less predictable what the outcomes of the review would be.

Figure 5 Acceptability curve (A) and population expected value of information (B) for comparing noninvasive positive pressure ventilation with standard therapy

pEVI: population expected value of information from review update with predicted outcomes for additional sample of n patients (i.e., pEVPI_prior_ - pEVPI_post_); pEVPI_prior_: population expected value of perfect information prior to updating review, based on available meta-analysis;138 pEVPI_post_: population expected value of perfect information with (posterior) predicted outcomes for review update with additional sample of n patients.

Figure 5 displays adjacents graphs of the acceptability curve and the population expected value of information (EVI) curves for comparing noninvasive positive pressure ventilation (NPPV) with standard sherapy. The graph on the left side displays the acceptability curve, and the graph on the right side displays 5 VOI curves. The first is the population expected value of information (or pEVPI) curve prior to updating a review on NPPV, based on data available from an existing meta-analysis [138], the second is the pEVPI curve with (posterior) predicted outcomes for a review update with an additional sample “n” of 500 patients, the third is the pEVI curve for a review update with for an additional sample “n” of 500 patient, which equals the difference between the pEVPI prior and the EVPI posterior a review update. The fourth curve is the pEVPI posterior curve with an “n” equal to 2000, and the last is the pEVI curve with an “n” equal to 2000. This figure is described further in the “Application, Application of a Minimal Modeling Approach to VOI, Use of Available Data on Comprehensive Outcome Measures: Noninvasive Positive Pressure Ventilation in Acute Respiratory Failure” section as follows: “As shown in Figure 5, the population expected VOI suggests that performing a systematic review to provide more precise estimates on the net benefit of NPPV compared with standard treatment in exacerbations of COPD is unlikely to be valuable over a wide range of threshold values for cost-effectiveness. Specifically, the pEVI is not expected to exceed the expected costs of $300,000 for a review update for a cost-effectiveness threshold less than $8000 or over $26,000 per life-year saved. For a more common threshold of $50,000 per life-year saved, the supplementary use of NPPV in acute respiratory failure is recommended without further research to inform this treatment decision. This is because of the statistically significant effect of treatment alternatives on in-hospital mortality-risk and hospital stay from meta-analysis [138]. The upper bounds on the value that can be expected from further research ( ) broadly range from $554,500 to $149.30 million for threshold values around $15,000/life-year for which the decision about optimal treatment of acute respiratory would change. Essentially, these VOI calculations are not very different from some standardized VOI estimates available, ranging from $2 million to $125 billion, for other studies [7]. The population value of updating a review (pEVI) on acute respiratory treatment varies considerably with the additional sample of patients that may be found. This value decreases with larger sample sizes because it then becomes less predictable what the outcomes of the review would be.”

We conclude that performing VOI through minimal modeling reveals that there is limited value to be expected from reducing uncertainty about the comparative effectiveness of NPPV versus standard therapy in acute respiratory failure. Based on these results, the updating of an earlier meta-analysis on treatment effects would seem to merit low priority, especially when the resources or budgets for research are limited and other systematic reviews exist for which VOI is calculated to exceed the costs of performing these reviews. The minimal modeling exercise in acute respiratory failure took just a few days of work, as opposed to what we expect would be months for a typical full-modeling approach to VOI.

## Conclusion

Our algorithmic approach to systematizing the use of VOI in prioritizing systematic reviews demonstrated to have potential utility in identifying effective and efficient VOI methods for prioritizing topics nominated to the AHQR EPCs for systematic review. As part of this, conceptual VOI, maximal modeling, and minimal modeling are often found to offer lower cost alternatives to typical full modeling approaches to VOI. In a series of clinically related empirical applications, we described how the use of these alternative approaches to VOI can potentially minimize the burden to the practical application of VOI and aid in setting priorities among all possible systematic reviews. As such, VOI may improve the effectiveness of research spending on systematic reviews.