# Minimal Modeling VOI in Acute Respiratory Failure in WinBUGS

#MODEL: COMPARATIVE EFFECTIVENESS OF Noninvasive Positive Pressure Ventilation vs STANDARD THERAPY
model
{
# MODELS FOR PRIOR ANALYSIS
lnrr_prior ~ dnorm(mu_lnrr_prior,  tau_lnrr_prior)
ilos_prior ~ dnorm(mu_ilos_prior, tau_ilos_prior)
for (i in 1 : 101)                                  # threshold value for cost-effectiveness (*1000-1000)
{
NB_prior[i] <- exp(lnrr_prior)*(1-exp(-bmr))*le*(i*1000-1000)/pow((1+beta), (le-1)) + ilos_prior*c_ilos - c_nppv
PrCE_prior[i] <- step(NB_prior[i])
pEVPI_prior.1[i] <- max(-NB_prior[i], 0)*((time*imp*dur*pop)/pow((1+beta), (time-1)))
pEVPI_prior.2[i] <- max(0, NB_prior[i])*((time*imp*dur*pop)/pow((1+beta), (time-1)))
}
# MODELS FOR SAMPLE & POSTERIOR ANALYSIS
for (nsc in 1:7)
{
       n[nsc] <- max(500, (nsc-1)*1000)    # expected additional sample of patients for review update)
       ybar_tau_lnrr[nsc] <- 1/((1/tau_lnrr_prior)*n_lnrr/n[nsc])
       ybar_lnrr[nsc] ~ dnorm(lnrr_prior, ybar_tau_lnrr[nsc])
       mu_lnrr_post[nsc] <- (ybar_lnrr[nsc]*ybar_tau_lnrr[nsc]/(tau_lnrr_prior + ybar_tau_lnrr[nsc]))
                          + (mu_lnrr_prior*tau_lnrr_prior/(tau_lnrr_prior + ybar_tau_lnrr[nsc]))
       ybar_tau_ilos[nsc] <- 1/((1/tau_ilos_prior)*n_ilos/n[nsc])
       ybar_ilos[nsc] ~ dnorm(ilos_prior, ybar_tau_ilos[nsc])
       mu_ilos_post[nsc] <- (ybar_ilos[nsc]*ybar_tau_ilos[nsc]/(tau_ilos_prior + ybar_tau_ilos[nsc]))
                                            + (mu_ilos_prior*tau_ilos_prior/(tau_ilos_prior + ybar_tau_ilos[nsc]))
for (k in 1 : 101)                                # threshold value for cost-effectiveness (*1000-1000)
{
NB_post[nsc, k] <- exp(mu_lnrr_post[nsc])*(1-exp(-bmr))*le*(k*1000-1000)/pow((1+beta), (le-1)) + mu_ilos_post[nsc]*c_ilos - c_nppv
PrCE_post[nsc, k] <- step(NB_post[nsc, k])
pEVPI_post.1[nsc, k] <- max(-NB_post[nsc, k], 0)*((time*imp*dur*pop)/pow((1+beta), (time-1)))
pEVPI_post.2[nsc, k] <- max(0, NB_post[nsc, k])*((time*imp*dur*pop)/pow((1+beta), (time-1)))
}
}
}
# DATA
list(mu_lnrr_prior = -0.80,          # mean log relative risk of in-hospital mortality
tau_lnrr_prior = 31.98,                # precision of distribution of log relative risk, 1/var() = 1/(ln(0.30)-ln(0.60))/2*1.96)^2
mu_ilos_prior = 1.94,                 # mean difference in length of hospital stay
tau_ilos_prior = 1.03,                 # precision of distribution of length of hospital stay, 1/var() = 1/(3.87-0.01)/2*1,96)^2
bmr = 0.25,                                  # baseline in-hospital mortality rate
le = 4.4,                                       # life expectancy, years
c_nppv = 7012,                           # costs of administring NPPV, $
c_ilos = 600,                               # costs of hospital stay per day, $
time = 5,                                     # time horizon of analysis, years
dur = 1,                                       # durability of information
imp = 0.10,                                 # implementation of NPPV, probability of implementation × tolerabilty of NPPV, 0,11*0,87
pop = 850000,                            # number of hospital admissions per year
beta = 0.03,                                 # discount rate
n_lnrr = 940,                               # sample of patients included in prior systematic review [Quon et al., 2008]
n_ilos = 956)                              # sample of patients included in prior systematic review [Quon et al., 2008]
end