# Potentially Relevant Health Care Decisionmaking Bodies and Research Funding Agencies

## FROM THE UNIVERSITY OF CHICAGO REPORT [21]

1. Programs for Assessment of Technology in Health (PATH) Research Institute – Canada^*^
  * Agencies that perform systematic reviews of health care
2. Medical Services Advisory Committee (MSAC) – Australia^*^
3. Australian Safety and Efficacy Register of New Interventional Procedures - Surgical (ASERNIP-D) – Australia^*^
4. Health Services Assessment Collaboration (HSAC) – New Zealand^*^
5. Dutch Health Care Insurance Board (CVZ) – Netherlands^*^
6. German Institute for Quality and Efficiency in Health Care (IQWiG) – Germany^*^

## FROM THE DUKE EVIDENCE-BASED PRACTICE CENTER REPORT [20]

### National Institutes of Health: Centers, Programs, and Individual Institutes

7 Division of Program Coordination, Planning and Strategic Initiatives, Office of Director, NIH^*^
8 Office of AIDS Research
9 Office of Behavioral and Social Sciences Research (OBSSR)
10 Office of Strategic Coordination (OSC), Office of Director, NIH
11 Office of Research in Women’s Health
12 National Cancer Institute (NCI)
13 National Eye Institute (NEI)
14 National Heart, Lung and Blood Institute (NHLBI)^§^
  § Agencies that develop clinical practice guidelines for which they synthesize evidence.
15 National Human Genome Research Institute (NHGRI)
16 National Institute of Aging(NIA)
17 National Institute of Alcohol Abuse and Alcoholism (NIAAA)
18 National Institute of Allergy and Infectious Diseases (NIAID)^§^
19 National Institute of Arthritis, Musculoskeletal and Skin Diseases (NIAMS)^*^
20 National Institute of Biomedical Imaging and Bioengineering (NIBIB)^*^
21 National Institute of Child Health and Human Development (NICHD)
22 National Institute on Deafness and other Communication Disorders (NIDCD)^*^
23 National Institute of Dental and Craniofacial Research (NIDCR)
24 National Institute of Digestive and Kidney Diseases (NIDDK)^*^
25 National Institute of Drug Abuse (NIDA)
26 National Institute of Environmental Health Science (NIEHS)
27 National Institute of General Medical Sciences (NIGMS)^*^
28 National Institute of Mental Health (NIMH)
29 National Institute of Neurological Disorders and Stroke (NINDS)^*^
30 National Institute of Nursing Research (NINR)^*^
31 NIH Consensus Statements

### Agency for Healthcare Research and Quality (AHRQ)

32 United States Preventive Services Task Force (USPSTF)^*^
  - They select topics, but commission the EPCs to do systematic reviews^*^
33 Developing Evidence to Inform Decisions about Effectiveness Network (DeCIDE) Centers
34 Centers for Education & Research on Therapeutics (CERTs)
35 Topic Selection for Systematic Reviews (EPCs)^*^

### Other U.S. Government Sponsors of Research

36 Centers for Disease Control and Prevention (CDC)^*^
37 Centers for Medicare and Medicaid Services (CMS)
38 Veterans Administration (VA)^*^
  - VA Technology Assessment Program^*^
39 U.S. Food and Drug Administration (FDA)^*^
40 U.S Agency for International Development (USAID)

### International Agencies and Groups

41 National Institute for Clinical Excellence (NICE) – UK^*^
42 Cochrane reviews and protocols^*^
43 Canadian Agency for Drugs and Technologies in Health (CADTH) – Canada^*^
44 Institutes for Health Services and Policy Research (IHSPR) – Canada^*^
45 German Research Foundation
46 German Federal Ministry of Education and Research
47 Australian Research Council
48 World Health Organization (WHO)^*^

### Non-governmental Sponsors of Research

49 American Cancer Society
50 Bill and Melinda Gates Foundation
51 Robert Wood Johnson Foundation
52 American Heart Association
53 March of Dimes^*^

## FROM NOORANI et al 2007 [93]

54 Agence d'évaluation des technologies et des modes d'intervention en santé (AETMIS) – Alberta, Quebec^*^
55 Alberta Heritage Foundation for Medical Research (AHFMR) – Alberta, Canada^*^
56 Unit of Health Economics and Health Technology Assessment (HunHTA) – Hungary^*^
57 Israel Center for Technology Assessment in Health Care (ICTAHC) – Israel^*^
58 Medical Advisory Secreteriat/ Ontario Health Technology Advisory Committee (MAS/OHTAC) – Ontario, Canada^*^
59 NIHR Coordinating Centre for Health Technology Assessment (NCCHTA) – UK^*^
  - Now called NIHR Evaluation, Trials and Studies Coordinating Centre (NETSCC)^*^
60 NHS Quality Improvement Scotland (NHS QIS) – Scotland, UK^*^
61 Basque Office for Health Technology Assessment (OSTEBA) – Spain^*^
62 Swedish Council on Health Technology Assessment (SBU) – Sweden^*^
63 The Medical and Health Research Council of The Netherlands (ZonMW) – Netherlands^*^

## OTHER

64 American Society for Clinical Oncology (ASCO) – U.S.^*^
65 Centre for Reviews and Dissemination (CRD) – U.K.^*^