# Search Criteria from Previous VOI and Priority-Setting Reports

Myers, E., et al., Evaluating the Potential Use of Modeling and Value-of-Information Analysis for Future Research Prioritization Within the Evidence-based Practice Center Program. 2011, AHRQ Publication No. 11-EHC030-EF.: Rockville, MD [20].

Search #1: Designed to identify articles addressing methods of priority setting, using the following search strategy (no date restrictions, search date October 22, 2010): ("Research"[Mesh] OR "Health Services Research"[Mesh]) AND (exercise[title/abstract] OR tool[title/abstract] OR tools[title/abstract] OR model[title/abstract] OR models[title/abstract] OR method[title/abstract] OR methods[title/abstract] OR "models, theoretical"[MeSH Terms] OR "costs and cost analysis"[MeSH Terms] OR "resource allocation"[MeSH Terms] OR "investments/economics"[Mesh Terms]) AND ("health priorities"[MeSH Terms] OR "priority setting"[title/abstract] OR "research priorities"[title/abstract] OR "research priority"[title/abstract])

Search #2: Designed to identify articles specifically addressing VOI, using the following search strategy (no date restrictions, search date December 1, 2010): "value of information"[title/abstract] AND (("Decision Making"[Mesh] OR "Decision Theory"[Mesh]) OR ("Research"[Mesh] OR "Health Services Research"[Mesh]) OR research[title/abstract])

Meltzer, D., et al., Minimal Modeling Approaches to Value of Information Analysis for Health Research. Methods Future Research Needs Report No. 6. 2011, AHRQ Publication No. 11-EHC062-EF.: Rockville, MD [21].

Search #1: We searched the MEDLINE database for English-language publications from January 1, 1990 to June 3, 2010, using the following exact search terms (in all fields): “value of information,” “value of additional information,” “value of information analysis,” “expected value of perfect information,” “EVPI,” “expected value of partial perfect information,” “EVPPI,” “Bayesian approach to uncertainty,” or “value of research.”

Search #2: Our grey literature search was limited to Internet sites of different health technology assessment (HTA) organizations and institutions in the United States, Canada, the U.K., Australia/New Zealand, The Netherlands, and Germany. Web sites were searched for: (1) VOI methods guidance intended to aid authors in completing a HTA, and (2) examples of VOI applications in individual HTA and systematic review publications.