# Abbreviations and Variables

Abbreviations
AHRQ: Agency for Healthcare Research and Quality
CADTH: Canadian Agency for Drugs and Technologies in Health
CHD: coronary heart disease
CI: confidence interval
COPD: chronic obstructive pulmonary disease
DEPC: Duke Evidence-based Practice Center
DERP: Drug Effectiveness Review Project
EHC: Effective Health Care
ENBS: expected net benefit from sampling
ENG: expected net gain of performing a trial
EPCs: Evidence-based Practice Centers
EVI: expected value of information
EVPI: expected value of perfect information
EVPPI: expected value of partial perfect information
EVSI: expected value of sample information
ICER_trial_: incremental cost-effectiveness ratio of performing a trial
NHS: National Health Services
NICE: National Institute for Health and Clinical Excellence
NIH: National Institutes of Health
NIHR HTA: National Institute for Health Research Health Technology Assessment program
NPPV: noninvasive positive pressure ventilation
OHTAC: Ontario Health Technology Advisory Committee
Osteba: Basque Office for Health Technology Assessment
pENBS: population expected net benefit of sampling
pENG: population expected net gain of performing a trial
pEVI: population expected value of information
pEVPI: population expected value of perfect information
pEVPPI: population expected value of partial perfect information
pEVSI: population expected value of sample information
QALY: quality-adjusted life-year
SBU: Swedish Council on Technology Assessment in Health Care
SIGN: Scottish Intercollegiate Guidelines Network
TEP: technical expert panel
UC: University of Chicago
USPSTF: U.S. Preventive Services Task Force
VOI: value of information
WHO: World Health Organization
ZonMw: Netherlands Organisation for Health Research and Development

Variables (in Order of Appearance in Text)
pEVI: population expected value of information from a particular set of information I from a research study or systematic review, in monetary terms
β^t^: discount rate for the future benefits and costs of information over time period t, β^t^ ∈ [0,1]
Dur_t_: probability that information from a particular research study or systematic review is durable at time period t, Dur_t_ ∈ [0,1]
Pop_j_: size of patient population expected to benefit from health intervention j, Pop_j _∈ [0,∞]
Im p_jt|I_: probability of implementation of health intervention j at time period t with and additional set of information I on parameter values θ′ Im p_jt|I _∈ [0,1]
E_θ|I_ NB[j,θ]: expected net benefit of health intervention j with additional set of information I on parameter values θ, in monetary terms
Im p_jt_: probability of implementation of health intervention j at time period t, Im p_jt _∈ [0,1]
E_θ_ NB[j,θ]: expected net benefit of health intervention j with uncertain parameter values θ, in monetary terms
EVI: expected value of information from a particular set of information I from a research study or systematic review, in monetary terms
I: particular set of information from a research study or systematic review, on parameter values θ
j: particular health intervention (including a clinical guideline or an implementation strategy), or set of mutually exclusive health care interventions, j ∈ [1,2,..,J]
λ: threshold value for cost-effectiveness or willingness-to-pay (e.g., $ per additional life-year or quality-adjusted life-year)
E_θ_ O(j,θ): expected outcomes of health intervention j with uncertain parameter values θ, in terms of life expectancy, quality of life or any other health outcome
E_θ_ C(j,θ): expected costs of health intervention j with uncertain parameter values θ, in $
t: time period for which a particular clinical or health policy decision is relevant, in years
Π_I_: population expected returns from performing value of information analysis to identify the priority for a particular research study or systematic review, in monetary terms
EVPI: expected value of perfect information, in monetary terms
EVPPI: expected value of perfect partial information, in monetary terms
C_It_: costs of performing a particular research study, which may include a systematic review, at time period t, in $
C_VOI_: costs of performing value of information calculations, in $