# Results

## Part One: Unstandardized Versus Standardized Effect Sizes

### Overview

Monte Carlo simulations (Part 1A) showed that leaving the effect size (ES) index in the original metric (UMD) presents little bias or loss of efficiency when distributions were normal, when there is no heterogeneity in effect sizes, and when the variances of the experimental and control group means are equal; yet, to the extent that these conditions deviate, standardizing (SMD) is better. The standardized metric presents the least bias under all conditions and is more efficient than the raw metric. Both metrics suffer under high skewness and kurtosis, although the SMD less so. A further simulation (Part 2B) showed that the two indexes converge in terms of bias, efficiency, and coverage when data are normally distributed and studies are homogeneous in gauging the parametric ES.

### Detailed Analysis, Part 1A

In this section we detail the initial Monte Carlo simulation study that we performed. In Detailed Analysis, Part 2, we describe a second simulation study that addressed issues that emerged from the first.

#### Bias

Figures 1 through 5 show the primary results comparing the UMD against the SMD in terms of bias. As these figures show, the SMD had less bias than did the UMD under all plotted circumstances. The two metrics approach the same level of bias only when skewness and kurtosis is minimal (Figure 1), but even here the SMD showed a slight advantage. More dramatic differences between the two appeared as skewness and kurtosis increase, under fixed-effects (τ^2^=0; see Figure 2), as the parametric effect size increases (Figure 3), as the mean sample size increases (Figure 4), and as the difference in variances between the two compared groups increases (Figure 5). (No figure for number of studies appears because it did not change the trends reported here.) Across these conditions, the UMD was more likely than the SMD to over-estimate the parametric effect size.

Figure 1 Bias of SMD and UMD as a function of asymmetries in the distributions underlying the effect size estimates

SMD = standardized mean difference; UMD = unstandardized mean difference

This figure shows the degree of bias for the SMD and UMD effect size indexes as a function of assymetries in the underlying distributions. The results show increasing bias as the variances compared grow more assymetrical.

Figure 2 Bias of SMD and UMD as a function of the between-studies variance of the distribution

SMD = standardized mean difference; UMD = unstandardized mean difference

This figure shows bias of SMD and UMD as a function of the between-studies variance of the distribution underlying the comparison. The standardized mean difference shows less bias than the unstandardized mean difference at all levels of between-studies variance. The difference is wider under fixed-effects (tau-squared=0) and narrower under random-effects assumptions (tau-squared>0).

Figure 3 Bias of SMD and UMD as a function of the parametric effect size

SMD = standardized mean difference; UMD = unstandardized mean difference

This figure shows the bias of SMD and UMD effect sizes indexes as a function of the parametric effect size. Bias is smaller for the UMD than the SMD at all levels of the parametric effect size, a difference that grows as the parametric effect size increases.

Figure 4 Bias of SMD and UMD as a function of mean sample size

SMD = standardized mean difference; UMD = unstandardized mean difference

Bias of the SMD and UMD effect size indexes as a function of mean sample size. Bias of the SMD is lower than that of the UMD at all levels of sample size. The difference is narrower for samples of 30 and then widens for samples of 50 and 80. It appears that the difference between the two indexes will remain constant after samples sized 80.

Figure 5 Bias of SMD and UMD as a function of heteroskedasticity

SMD = standardized mean difference; UMD = unstandardized mean difference

Bias of the SMD and UMD effect size indexes as a function of the equivalence of the underlying variances (or heteroskedasticy). The SMD is less biased than the UMD across all levels of compared variances, although both indexes perform worse as the compared variances become more unequal. Bias increases at a sharper rate for the UMD than for the SMD.

#### Efficiency

Figures 6 through 10 show the primary results comparing the UMD against the SMD in terms of efficiency, such that values nearer to 0 are more efficient (i.e., values close to zero reflect less variability, so more efficiency to detect a difference between the compared groups’ means). The SMD presented more efficient estimations than the UMD under the same circumstances as it exhibited less efficiency. Specifically, the two metrics approach the same efficiency only when skewness and kurtosis is minimal (Figure 6), but even here the SMD showed a slight advantage. More dramatic differences between the two appeared as skewness and kurtosis increase, under increasing heterogeneity (τ^2^>0; see Figure 7), across all levels of the parametric effect size (Figure 8), across all levels of mean sample size (Figure 9), and as the difference between the variances of the two groups increases (Figure 10). Across these conditions, the UMD was a less efficient estimator than the SMD. The efficiency of SMD improves when the between-studies variance increases (τ^2^>0) or the sample size increases; it is not affected by the rest of the factors (and these are not plotted in the main report; see Appendix A, Tables A1 to A8 for more detailed results).

Figure 6 Efficiency of SMD and UMD as a function of asymmetry

SMD = standardized mean difference; UMD = unstandardized mean difference

This figure shows that the SMD is more efficient than the UMD effect size metric across all manipulated levels of asymmetry. The difference is small when assymmetries are minor but grows when assymetries grow. Both indexes perform worse as assymetries grow, but the problem is less for the SMD than for the SMD.

Figure 7 Efficiency of SMD and UMD as a function of between-studies variance

SMD = standardized mean difference; UMD = unstandardized mean difference

This figure shows the efficiency of SMD and UMD effect size indexes as a function of between-studies variance. The SMD always has better efficiency than the UMD and this advantage for the SMD grows as between-studies variance increases (i.e., under random-effects assumptions).

Figure 8 Efficiency of SMD and UMD as a function of the parametric effect size

SMD = standardized mean difference; UMD = unstandardized mean difference

This figure shows the efficiency of SMD and UMD effect size indexes as a function of the parametric effect size. The SMD is more efficient than the UMD at all levels of parametric effect size, and the difference does not change as the parametric effect size increases.

Figure 9 Efficiency of SMD and UMD as a function of mean sample size

SMD = standardized mean difference; UMD = unstandardized mean difference

This figure shows the efficiency of SMD and UMD effect size indexes as a function of mean sample size. The SMD always has better efficiency than the UMD and the difference between them is constant across levels of sample size. Efficiency is better for both indexes as sample sizes increase.

Figure 10 Efficiency of SMD and UMD as a function of the heteroskedasticity

SMD = standardized mean difference; UMD = unstandardized mean difference

This figures shows the efficiency of the SMD and UMD effect size indexes as a function of the ratio of observed variances between the compared conditions (i.e., heteroskedasticity). Efficiency of the SMD is better at all levels compared to the UMD. The UMD becomes less efficient as the differences between the variances increase, whereas the efficiency of the SMD does not change.

### Detailed Analysis, Part 1B

We followed the same procedures in a subsequent Monte Carlo simulation study in order to explore the performance of the two indexes, SMD and UMD, when a weighted mean effect size is obtained under particular conditions and evaluating the 95% confidence interval (CI) coverage; the previous simulation evaluated only whether individual studies approximated the parametric effect size. We envisioned circumstances that might be regarded as “well-behaved data” compared with “unruly” data, where both types of data gauged the same parametric medium effect size (δ=0.50). For our well-behaved data, we simulated normal distributions with no skewness or kurtosis, large sample sizes (M n = 80), and a large number of studies (k = 100). We conceived of two unruly data conditions with the same parameters, except that in one the experimental vs. control variances very unequal (4:1), and in the other there was an extremely nonnormal distribution (skewness/kurtosis = 1.75/3.75). There were 10,000 replications in each condition. Note that these conditions do not evaluate random-effects circumstances (i.e., τ^2^=0 in this simulation).

Bias and efficiency were obtained across the replications as in Part 1, but coverage of the confidence interval also was obtained specially for this set of simulations. Thus, the final average weighted effect size across the individual studies was generated along with a 95% confidence interval around the mean effect size. Then the coverage of their confidence intervals was obtained as the proportion of replications in which the confidence interval for each index did not include the null value, ES = SMD = UMD = 0.

In obtaining the weighted ES, the SMD and UMD indexes exhibited bias and efficiency that were only trivially different (Table 7). Both slightly overestimated the parametric ES under either the normal data circumstance or the nonnormal distributions, and both dramatically overestimated the ES under circumstances of unequal variances. These results serve as a form of replication of the results of Part 1A.

Table 7 Bias, efficiency, and 95% CI coverage for the SMD and UMD under three different inferential circumstances

Statistic | Normal Data, Equal Variances, Large Samples | Unequal Variances (4:1) | Skewness/Kurtosis (1.75/3.75)
Bias
SMD | 0.0169 | 0.3153 | 0.0256
UMD | 0.0170 | 0.3250 | 0.0572
Efficiency
SMD | 0.0824 | 0.1055 | 0.1564
UMD | 0.0852 | 0.1047 | 0.1587
95% CI Coverage
SMD | 0.9521 | 0.9328 | 0.9146
UMD | 0.9567 | 0.9339 | 0.9197

CI = confidence interval; SMD = standardized mean difference; UMD = unstandardized mean difference

The coverage of their CIs indicates that both the SMD and UMD estimations include the true value in 95 percent of the simulations. In some occasions, both CIs missed the parameter under unequal variances or when nonnormal distributions are present.

## Part Two: Using the SMD with Repeated Versus Independent Measures

### Overview

- If one is interested in analyzing the effects of an intervention excluding time-related effects, then it is convenient to consider the raw-score metric. That is, research routinely controls for the stability of observations of particular cases across time. If a treatment affects an outcome uniformly across cases, then a perfect correlation between pre- and post-test observations is implied. Treatments that affect the outcome differentially across cases and time imply a correlation that is less than 1. Statistical analyses in primary-level statistics routinely control for this within-subjects variability (see, for example Pedhauzer, 1997^17^). In meta-analytic statistics, debate exists about whether to control for this source of variability (see Tables 1–4).
- The Monte Carlo simulation systematically compared estimates for effect size (Tables 1–2) and the sampling variance (Tables 3–4) across studies that varied in the magnitude of the correlation between the pre- and post-tests (ρ=0, 0.25, 0.50, 0.75).
- Because the main factor that affected estimates was the magnitude of the correlation between the two measures, other simulated conditions are not presented here (see Appendix B).

### Detailed Analysis

#### One-Group Within-Subjects Design

The simulation evaluated bias, efficiency for five different indexes designed for the one-group, within-subjects design, d_tra_, d_tch_, d_b_, d_g_, d_hw_ (see Table 1). The simulation also evaluated d_hb_ (Table 2, equation 6) even though it was designed for a two-group comparison.34 As well as the theoretical variance adjustment for the variance estimations that have been presented in the literature and combining them across the different indexes.

##### Bias

Figure 11 shows bias of the six different indexes calculated as the difference between the mean of the two repeated observations and the parametric ES in raw metric, δ_raw_, over the replications in each correlation condition, assuming normality of distributions. Positive values reflect an overestimation of this particular parameter, whereas negative values imply an underestimation.)

Figure 11 Bias as a function of the correlation parameter of ES indexes for the one-group, within-subjects design

<br1>d_b_ = Becker’s standardized mean difference; d_g_ = Gibbons’s standardized mean difference; d_hb_ = Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_ = Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom; d_tch_ = the standardized mean difference in change-score metric from t_d_; d_tra_ = standardized mean difference in raw-score metric form t_d_

This figure shows bias as a function of the correlation between repeated observations. Bias is minimal for two indexes, regardless of the magnitude of the correlation: (1) Becker’s standardized mean difference; and (2) the standardized mean difference in raw-score metric. The other indexes deviate from the zero value indicating no bias, sometimes dramatically. All indexes converge on zero bias when the correlation is 0.5, except for the Huedo-Medina and Johnson standardized mean difference effect size using the within-study degrees of freedom, which always estimates the effect size smaller than it should be.

Of all ES indexes, d_b_ and d_tra_ were the least biased across all correlations and their performance are exactly the same as d_hb_. Two others had no bias when the correlation was 0.5, d_g_ and d_tch_, but underestimated the parametric ES when the correlation was smaller and overestimated it when the correlation was larger. The remaining index in Figure 11 (one that does not explicitly incorporate the correlation in its equation), d_hw_ consistently underestimated the ES regardless of the correlation (see Appendix B, Table B2, for more detail).

##### Efficiency

As Figure 12 shows, the most efficient ES index was d_hw_ and its efficiency improved as the correlation between the measures grew. Its efficiency was only slightly better than d_tch_ and d_g_ when ρ=0. Moreover, d_b_, d_tra_, and d_hb_ had the lowest efficiency when the repeated measures were less correlated but did better when they were highly correlated. The other two indexes, d_g_ and d_tch_, performed worse under high correlation conditions and better under low correlation conditions. Estimates for d_g_ and d_tch_ are almost unaffected by increasing the assumed correlation between pre- and post-test, although these increase slightly as the correlation increases. Although efficiency is similar for all alternatives when the correlation is 0.5, d_g_ and d_tch_ are more variable than any other when the correlation is larger than 0.5.

Figure 12 Efficiency as a function of the correlation parameter of the ES indexes

d_hb_ = Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_ = Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom; d_tra_ = standardized mean difference in raw-score metric form t_d_; d_tch_ = the standardized mean difference in change-score metric from t_d_; d_b_ = Becker’s standardized mean difference; d_g_ = Gibbons’s standardized mean difference

This figure shows the efficiency of the effect size indexes as a function of how correlated the repeated observations are. The text describes other patterns displayed here.

##### The Theoretical Variance Adjustment

Figure 13 shows how the correlation parameter relates to adjustments to the theoretical variance in the two-groups design with repeated measures. Note that here results for d_hb_, d_hw_, and d_b_ used variance equation 13 and d_g_ used equation 14 (see Table 3).The least biased estimations of the variance are d_g_ and d_b_. The difference between the theoretical and the empirical variance decreases slightly for d_g_ as the correlation increases if the latter is smaller than 0.5, however, an opposite pattern is observed if the correlation is larger than 0.5. However, the theoretical variance adjustment of d_b_ always decreases as the correlation increases. The worst adjustment is for d_hb_ and then for d_hw_; both present a difference that decreases as the correlation increases.

Figure 13 The theoretical variance adjustment to the empirical variance as a function of the correlation parameter of the ES indexes

d_hb_ = Hedges’s standardized mean difference using the between-studies degrees of freedom (Equation 13, Table 3); d_hw_ = Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom (Equation 13, Table 3); d_b_ = Becker’s standardized mean difference (Equation 13, Table 3); d_g_ = Gibbons’s standardized mean difference (Equation 14, Table 3)

This figure shows the theoretical variance adjustment to the empirical variance for the effect size indexes as a function of how correlated the repeated observations are. The text describes other patterns displayed here.

If the theoretical variance is calculated for d_hw_ and d_b_ without including the correlation factor, 2(1 − ρ), and using the df = n − 1 and ñ = n, d_hw_nonr_ and d_b_nonr_, these indexes present opposite patterns to their corresponding versions including the correlation factor, as Figure 14 illustrates.

Figure 14 The theoretical variance adjustment to the empirical variance as a function of the correlation parameter of the ES indexes

d_b_ = Becker’s standardized mean difference; d_b_nonr_ = Becker’s standardized mean difference without including the correlation factor 2(1 − r) in its equation (Equation 13, Table 3); d_g_ = Gibbons’s standardized mean difference (Equation 14, Table 3); d_hb_ = Hedges’s standardized mean difference using the between-studies degrees of freedom (Equation 13, Table 3); d_hw_ = Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom (Equation 13, Table 3); d_hw_nonr_ = Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom without including the correlation factor 2(1 − r) in its equation (Equation 14, Table 3)

This figure shows the theoretical variance adjustment to the empirical variance of the ES indexes as a function of the correlation parameter. The text describes other patterns displayed here.

#### Two-Group Repeated Measures Designs

The simulation evaluated bias, efficiency, and theoretical variance adjustment for seven different estimates of effect sizes (ESs) for the two-groups designs with repeated measures, d_hb_, d_b_, d_g_, d_hw_, d_s1_, d_s2_, and d_s3_ (see Table 2). One of these, d_hb_ (Table 2, equation 6) was designed to focus on a two-group comparison at one measurement point (without considering repeated measures); the others utilize an earlier measure in some respect.

##### Bias

As Figure 15 shows, two ES indexes present no bias in estimating the parametric ES, d_s1_ and d_s2_. The denominator for each of these equations incorporates the correlation between the two measures in some respect (in the standard deviation or in the mean square error). The other indexes ignore the correlation between the measures and usually exhibit a negative bias. The only exception is that if the measures are correlated moderately (ρ = 0.5), d_g_ performs with no bias; this ES underestimates the parametric effect size when the measures are less correlated and overestimates it when they are more correlated.

Figure 15 Bias as a function of the correlation parameter of the ES indexes

d_hb_ = Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_ = Huedo-Medina and Johnson’s standardized mean difference; d_b_ = Becker’s standardized mean difference; d_g_ = Gibbons’ standardized mean difference; d_s1_ = standardized mean difference using Shadish’s pooled standard deviation; d_s2_ = standardized mean difference using the ANOVA data; d_s3_ = standardized mean difference from ANCOVA data

This figure shows amount of bias for the effect size indexes as a function of how correlated the repeated observations are in the two-group repeated measures design. The text describes other patterns displayed here.

The three new ES indexes presented for two-groups design are those calculated from ANOVAs, d_s1_ and d_s2_, and one from ANCOVA, d_s3_. The performance of the two first is the same as those estimating a parametric ES in raw-score metric, so they do not present bias. However, the third one underestimates the parameter but improves as the correlation increases.

##### Efficiency

In general, in terms of efficiency the best estimator is d_hw_ and then d_s1_, d_s2_, d_s3_, and d_g_ are very similar if correlation is lower than 0.5. However, when ρ > 0.5 the efficiency of d_g_ increases drastically, as it was shown in one-group design. The indexes d_hb_ and d_b_ have very similar efficiency, with d_b_ being slightly larger when ρ = 0; when ρ = 0.5, the variability of d_hb_ is slightly larger than d_b_ (see Figure 16).

Figure 16 Efficiency as a function of the correlation parameter of the ES indexes

d_hb_ = Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_ = Huedo-Medina and Johnson’s standardized mean difference; d_b_ = Becker’s standardized mean difference; d_g_ = Gibbons’ standardized mean difference; d_s1_ = standardized mean difference using Shadish’s pooled standard deviation; d_s2_ = standardized mean difference using the ANOVA data; d_s3_ = standardized mean difference from ANCOVA data

This figure shows the efficiency of the ES indexes as a function of how correlated the repeated measures are (in the case of the two-group repeated measures design). No matter how correlated the measures are, the best estimator is Hedges’s standardized mean difference using the within-study degrees of freedom.

##### The Theoretical Variance Adjustment

Figures 17 and 18 present the differences between the sampling variance estimates and the actual sampling variance of the effect size index. First, in Figure 17, the estimates illustrated using a solid line are calculated as the variance of an ES, and those dashed lines are obtained as a variance compound of two variances, one for the ES of each independent group. The effect size indexes that require the least theoretical variance adjustment are d_s1_, d_s3_, d_g_, and d_hw_, with the latter two effect sizes defined in such a way that the variance calculated for a total ES is calculated as a difference between the ES for each group. The effect size indexes that required the largest theoretical variance adjustment are d_g_, d_hw_, and d_g_. The correlation between the measures has relatively little role in affecting the theoretical variance adjustment. (Note that d_s2_ is not considered in Figure 17 because it has exactly the same performance as d_s1_.). The considerably worse performance appears in those estimates of the sampling variance that are a composite of the experimental and control group variance.

Figure 17 The theoretical variance adjustment to the empirical variance as a function of the correlation parameter of the ES indexes

d_hb_ = Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_ = Huedo-Medina and Johnson’s standardized mean difference; d_b_ = Becker’s standardized mean difference; d_g_ = Gibbons’ standardized mean difference; d_s1_ = standardized mean difference using Shadish’s pooled standard deviation; d_s2_ = standardized mean difference using the ANOVA data; d_s3_ = standardized mean difference from ANCOVA data

This figure shows the theoretical variance adjustment to the empirical variance of the ES indexes as a function of the correlation parameter (two-group repeated measures design). The text describes other patterns displayed here.

Figure 18 The theoretical variance adjustment to the empirical variance as a function of the correlation parameter of the ES indexes

d_hw_= Hedges’s standardized mean difference using the within-study degrees of freedom; d_b_ = Becker’s standardized mean difference; d_g_ = Gibbons’s standardized mean difference; note that the inclusion or exclusion of the correlation factor, 2(1-ρ), is denoted as _r and _nonr, respectively, in the suffix of these terms

This figure shows the sampling variance estimations for different ES metrics when including or excluding the correlation factor, 2 times (1 − rho), as a function of the correlation between the repeated measures. The text describes other patterns displayed here.

Figure 18 shows the sampling variance estimations for a total ES in different metrics, examining those that can include vs. exclude the correlation factor, 2(1 − ρ), d_hw_, d_b_, and d_g_. As expected, when the correlation factor was not included, all three indexes required the same theoretical variance adjustment regardless of the correlation between the measures. When the correlation factor is included, all exhibit similar trends, with better performance when ρ < 0.5 and worse performance when ρ > 0.5. Finally, if ρ = 0.5, all six indexes performed similarly.