# References

1 Sutton AJ, Duval SJ, Tweedie RL, et al. Empirical assessment of effect of publication bias on meta-analyses. BMJ. 2000;320(7249):1574-7. [pmid: 10845965].
2 Rothstein H, Sutton AJ, Borenstein M. Publication bias in meta-analysis. Rothstein HR, Sutton AJ, Borenstein M, editors. Publication bias in meta-analysis: prevention, assessment and adjustments. Chichester, UK. Wiley. 2005.
3 Rosenthal R. Meta-analytic procedures for social research. Rev ed. Newbury Park. Sage Publications. 1991.
4 Juni P, Altman DG, Egger M. Systematic reviews in health care: assessing the quality of controlled clinical trials. BMJ. 2001;323(7303):42-6. [pmid: 11440947].
5 Johnson BT, Boynton MH. Cumulating evidence about the social animal: meta-analysis in social-personality psychology. Society & Personality Psychology Compass. 2008;2:817-41.
6 Hunter JE, Schmidt FL. Methods of meta-analysis: correcting error and bias in research findings. 2nd ed. Thousand Oaks, CA. Sage. 2004.
7 Huedo-Medina TB, Johnson BT. Modelos Estadísticos en Meta-análisis. Statistical Models in Meta-analysis. La Coruna, Spain. Netbiblio. 2010.
8 Hedges LV, Olkin I. Statistical methods for meta-analysis. Orlando. Academic Press. 1985.
9 Cooper HM, Hedges LV, Valentine JC. The handbook of research synthesis. New York. Russell Sage Foundation. 2009.
10 Cooper H. Integrative research: A guide for literature reviews. 3rd ed. Newbury Park, CA. Sage. 1998.
11 Glass GV, McGaw B, Smith ML. Meta-analysis in social research. Beverly Hills. Sage Publications. 1981.
12 Glaser RR. Accuracy of ES calculation methods for repeated measures. [dissertation]. University of Memphis. 2002.
13 Ray JW, Shadish WR. How interchangeable are different estimators of effects size?. J Consult Clin Psychol. 1996;64:1316-25. [pmid: 8991318].
14 Bond CF Jr, Wiitala WL, Richard FD. Meta-analysis of raw mean differences. Psychol Methods. 2003;8:406-18. [pmid: 14664679].
15 Tukey JW. Analyzing data: sanctification or detective work?. Am Psychol. 1969;24:83-91.
16 Blalock HM. Causal inferences in non-experimental research. Chapel Hill. University of North Carolina Press. 1964.
17 Pedhazur EJ. Multiple Regression in Behavioral Research: Explanation and Prediction. New York. Holt, Rinehart and Winston. 1997.
18 Lipsey MW, Wilson DB. Practical Meta-analysis. Thousand Oaks, CA. Sage Publications. 2001;49.
19 Becker BJ. Synthesizing standardized mean-change measures. Br J Math Stat Psychol. 1988;41:257-278.
20 Cortina JM, Nouri H. ES for ANOVA designs. Thousand Oaks, CA. Sage. 2000.
21 Dunlap WP, Cortina JM, Vaslow JB, Burke MJ. Meta-analysis of experiments with matched groups or repeated measures designs. Psychol Methods. 1996;1:170-177.
22 Morris SB, DeShon RP. Combining effect size estimates in meta-analysis with repeated measures and independent-group designs. Psychol Methods. 2002;7:105-125. [pmid: 11928886].
23 Gibbons RD, Hedeker DR, Davis JM. Estimation of ES from a series of experiments involving paired comparisons. J Educ Stat. 1993;18:271-279.
24 Huedo-Medina T, Johnson BT. Standardized mean difference ES estimations for repeated-measures with continuous measures. 2011.
25 Hedges LV. Distribution theory for Glass’s estimator of effect size and related estimators. J Educ Behav Stat. June. 20. 1981;6(2):107-128.
26 Shadish WR, Robinson L, Lu C. ES: A computer programs for ES calculation. St Paul, MN. Assesment Systems Corporation. 1999.
27 Matsumoto M, Nishimura T. Mersenne twister: a 623-dimensionally equidistributed uniform pseudo-random number generator. ACM Trans Model Comput Simul. 1998;8(1):3-30.
28 Wilcox RR. New designs in analysis of variance. Annu Rev Psychol. 1987;38:29-60.
29 McWilliams L. Variance heterogeneity in empirical studies in education and psychology. Paper presented at the annual colloquium of the American Educational Research Association. San Francisco. 1991.
30 Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale, NJ. Lawrence Erlbaum Associates. 1988.
31 Fleishman AI. A method for simulating nonnormal distributions. Psychometrika. 1978;43:521-31.
32 Overton RC. A comparison of fixed-effects and mixed (random-effects) models for meta-analysis tests of moderator variable effects. Psychol Methods. 1998;3:354-79.
33 Biggerstaff BJ, Tweedie RL. Incorporating variability estimates of heterogeneity in the random effects model in meta-analysis. Stat Med. 1997;16:753-68. [pmid: 9131763].
34 Johnson BT, Eagly AH. Quantitative synthesis of social psychological research. Reis HT, Judd CM, editors. Handbook of Research Methods in Social and Personality Psychology. London. Cambridge University Press. 2000:496-528.
35 Cohen J. Quantitative methods in psychology: A power primer. Psychol Bull. 1992;112(1):155-9. [pmid: 19565683].