# Peer Reviewers

- Dr. Juan Botella
  Facultad de Psicología
  Universidad Autónoma de Madrid
  Madrid, Spain
- Dr. Carmen Ortego-Mate
  Departamento de Enfermería
  Departamento de Ciencias Medicas y Quirúrgicas
  University of Cantabria
  Santander, Spain
- Terri Pigott, Ph.D.
  Loyola University Chicago
  School of Education
  Chicago, IL
- Tom D. Stanley, Ph.D.
  Department of Economics
  Hendrix College
  Conway, AR
- David B. Wilson, Ph.D.
  Criminology, Law and Society
  George Mason University
  Fairfax, VA