# Acknowledgments

The authors gratefully acknowledge comments from Dr. Parivash Nourjah (TOO), Dr. Issa J. Dahabreh, and the peer reviewers on prior drafts of this report.