# Bias, Efficiency, and Theoretical Variance for All Effect Size Indexes and Their Variances (Specific Aim 2)

This appendix provides detailed tables for the results of the Specific Aim 2, including the bias, efficiency, and theoretical variance adjusted for all the effect size indexes and their variances.

Table B-1 Bias of repeated measures es indexes under differing sample sizes (n) and correlations (r) between the pretest and post-test

n | r | d_hb_ | d_hw_ | d_tra_ | d_tch_ | d_b_ | d_g_
50 | .00 | 0.0001 | −0.1491 | 0.0074 | −0.1412 | −0.0004 | −0.1467
50 | .25 | −0.0007 | −0.1497 | 0.0059 | −0.0869 | −0.0010 | −0.0933
50 | .50 | 0.0019 | −0.1478 | 0.0084 | 0.0084 | 0.0010 | 0.0006
50 | .75 | 0.0034 | −0.1468 | 0.0084 | 0.3038 | 0.0009 | 0.2914
75 | .00 | 0.0010 | −0.1475 | 0.0066 | −0.1418 | 0.0011 | −0.1454
75 | .25 | 0.0002 | −0.1481 | 0.0052 | −0.0875 | −0.0002 | −0.0917
75 | .50 | −0.0005 | −0.1486 | 0.0040 | 0.0040 | −0.0009 | −0.0011
75 | .75 | 0.0017 | −0.1471 | 0.0048 | 0.2982 | 0.0001 | 0.2901
100 | .00 | 0.0012 | −0.1469 | 0.0051 | −0.1428 | 0.0011 | −0.1455
100 | .25 | 0.0004 | −0.1475 | 0.0034 | −0.0890 | 0.0003 | −0.0921
100 | .50 | −0.0003 | −0.1480 | 0.0031 | 0.0031 | −0.0006 | −0.0007
100 | .75 | 0.0020 | −0.1464 | 0.0043 | 0.2974 | 0.0008 | 0.2913
250 | .00 | 0.0001 | −0.1469 | 0.0014 | −0.1455 | 0.0002 | −0.1465
250 | .25 | 0.0003 | −0.1467 | 0.0016 | −0.0904 | 0.0004 | −0.0916
250 | .50 | −0.0004 | −0.1473 | 0.0010 | 0.0010 | −0.0007 | −0.0005
250 | .75 | 0.0001 | −0.1469 | 0.0014 | 0.2928 | −0.0005 | 0.2904
500 | .00 | 0.0002 | −0.1466 | 0.0011 | −0.1457 | 0.0005 | −0.1462
500 | .25 | 0.0010 | −0.1460 | 0.0018 | −0.0903 | 0.0010 | −0.0909
500 | .50 | 0.0003 | −0.1465 | 0.0014 | 0.0014 | 0.0000 | 0.0006
500 | .75 | 0.0000 | −0.1467 | 0.0005 | 0.2913 | −0.0005 | 0.2902
750 | .00 | −0.0001 | −0.1467 | 0.0003 | −0.1462 | 0.0000 | −0.1466
750 | .25 | −0.0006 | −0.1470 | −0.0001 | −0.0918 | −0.0008 | −0.0923
750 | .50 | 0.0002 | −0.1465 | 0.0005 | 0.0005 | 0.0001 | 0.0000
750 | .75 | 0.0007 | −0.1461 | 0.0008 | 0.2919 | 0.0006 | 0.2911

Note. See Tables 1 and 2 in the main report for definitions of each effect size index. Bias is defined as the M difference between the estimate of the ES and the parametric value. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom; d_tch_=the standardized mean difference in change-score metric from t_d_; d_tra_=standardized mean difference in raw-score metric form t_d_.

Table B-2 Bias for repeated measures es indexes as a function of the correlations (r) between the repeated measures

r | d_hb_ | d_hw_ | d_tra_ | d_tch_ | d_b_ | d_g_
.00 | 0.0004 | −0.1473 | 0.0037 | −0.1439 | 0.0037 | −0.1462
.25 | 0.0001 | −0.1475 | 0.0030 | −0.0893 | 0.0032 | −0.0920
.50 | 0.0002 | −0.1475 | 0.0031 | 0.0031 | 0.0031 | −0.0002
.75 | 0.0013 | −0.1467 | 0.0034 | 0.2959 | 0.0035 | 0.2908

Note. See Tables 1 and 2 in the main report for definitions of each effect size index. Bias is defined as the M difference between the estimate of the ES and the parametric value. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom; d_tch_=the standardized mean difference in change-score metric from t_d_; d_tra_=standardized mean difference in raw-score metric form t_d_.

Table B-3 Efficiency of the ES indexes under differing sample sizes (n) and correlations (r) between the pretest and post-test

n | r | d_hb_ | d_hw_ | d_tra_ | d_tch_ | d_b_ | d_g_
50 | .00 | 0.0413 | 0.0206 | 0.0426 | 0.0224 | 0.0432 | 0.0217
50 | .25 | 0.0303 | 0.0152 | 0.0312 | 0.0222 | 0.0321 | 0.0215
50 | .50 | 0.0212 | 0.0106 | 0.0217 | 0.0230 | 0.0226 | 0.0223
50 | .75 | 0.0101 | 0.0051 | 0.0103 | 0.0274 | 0.0107 | 0.0266
75 | .00 | 0.0269 | 0.0135 | 0.0275 | 0.0144 | 0.0282 | 0.0141
75 | .25 | 0.0210 | 0.0105 | 0.0214 | 0.0151 | 0.0221 | 0.0147
75 | .50 | 0.0146 | 0.0073 | 0.0149 | 0.0158 | 0.0155 | 0.0155
75 | .75 | 0.0066 | 0.0033 | 0.0067 | 0.0176 | 0.0070 | 0.0173
100 | .00 | 0.0202 | 0.0101 | 0.0206 | 0.0108 | 0.0210 | 0.0106
100 | .25 | 0.0159 | 0.0079 | 0.0161 | 0.0112 | 0.0167 | 0.0110
100 | .50 | 0.0106 | 0.0053 | 0.0108 | 0.0115 | 0.0113 | 0.0113
100 | .75 | 0.0051 | 0.0025 | 0.0051 | 0.0131 | 0.0053 | 0.0129
250 | .00 | 0.0081 | 0.0040 | 0.0081 | 0.0042 | 0.0083 | 0.0042
250 | .25 | 0.0062 | 0.0031 | 0.0062 | 0.0043 | 0.0065 | 0.0043
250 | .50 | 0.0043 | 0.0022 | 0.0044 | 0.0046 | 0.0045 | 0.0046
250 | .75 | 0.0021 | 0.0010 | 0.0021 | 0.0053 | 0.0021 | 0.0053
500 | .00 | 0.0041 | 0.0020 | 0.0041 | 0.0021 | 0.0042 | 0.0021
500 | .25 | 0.0032 | 0.0016 | 0.0032 | 0.0023 | 0.0034 | 0.0022
500 | .50 | 0.0021 | 0.0011 | 0.0021 | 0.0023 | 0.0022 | 0.0023
500 | .75 | 0.0010 | 0.0005 | 0.0010 | 0.0026 | 0.0010 | 0.0026
750 | .00 | 0.0027 | 0.0013 | 0.0027 | 0.0014 | 0.0028 | 0.0014
750 | .25 | 0.0021 | 0.0011 | 0.0021 | 0.0015 | 0.0022 | 0.0015
750 | .50 | 0.0015 | 0.0007 | 0.0015 | 0.0015 | 0.0015 | 0.0015
750 | .75 | 0.0007 | 0.0003 | 0.0007 | 0.0018 | 0.0007 | 0.0018

Note. See Tables 1 and 2 in the main report for definitions of each effect size index. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom; d_tch_=the standardized mean difference in change-score metric from t_d_; d_tra_=standardized mean difference in raw-score metric form t_d_.

Table B-4 Efficiency for the ES indexes as a function of the correlation (r) between pretest and post-test

r | d_hb_ | d_hw_ | d_tra_ | d_tch_ | d_b_ | d_g_
.00 | 0.0172 | 0.0086 | 0.0176 | 0.0092 | 0.0180 | 0.0090
.25 | 0.0131 | 0.0066 | 0.0134 | 0.0094 | 0.0138 | 0.0092
.50 | 0.0091 | 0.0045 | 0.0092 | 0.0098 | 0.0096 | 0.0096
.75 | 0.0043 | 0.0021 | 0.0043 | 0.0113 | 0.0045 | 0.0111

Note. See Tables 1 and 2 in the main report for definitions of each effect size index. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom; d_tch_=the standardized mean difference in change-score metric from t_d_; d_tra_=standardized mean difference in raw-score metric form t_d_.

Table B-5 Theoretical variance adjustment to the empirical variance under differing sample sizes (n) and correlations (r) between the pretest and post-test

n | r | d_hb_ | d_hw_ | d_b_ | d_g_
50 | .00 | 0.0375 | 0.0226 | 0.0018 | 0.0217
50 | .25 | 0.0284 | 0.0176 | 0.0023 | 0.0120
50 | .50 | 0.0171 | 0.0118 | 0.0013 | 0.0017
50 | .75 | 0.0037 | 0.0047 | 0.0005 | −0.0102
75 | .00 | 0.0252 | 0.0149 | 0.0012 | 0.0142
75 | .25 | 0.0177 | 0.0110 | 0.0004 | 0.0071
75 | .50 | 0.0107 | 0.0073 | 0.0001 | 0.0001
75 | .75 | 0.0025 | 0.0031 | 0.0003 | −0.0067
100 | .00 | 0.0188 | 0.0110 | 0.0008 | 0.0105
100 | .25 | 0.0132 | 0.0081 | 0.0000 | 0.0053
100 | .50 | 0.0083 | 0.0056 | 0.0003 | 0.0003
100 | .75 | 0.0018 | 0.0022 | 0.0001 | −0.0051
250 | .00 | 0.0075 | 0.0043 | 0.0002 | 0.0042
250 | .25 | 0.0054 | 0.0032 | 0.0001 | 0.0021
250 | .50 | 0.0032 | 0.0021 | 0.0000 | 0.0000
250 | .75 | 0.0007 | 0.0008 | 0.0000 | −0.0022
500 | .00 | 0.0037 | 0.0021 | 0.0001 | 0.0020
500 | .25 | 0.0025 | 0.0015 | −0.0001 | 0.0009
500 | .50 | 0.0016 | 0.0011 | 0.0000 | 0.0000
500 | .75 | 0.0004 | 0.0004 | 0.0000 | −0.0011
750 | .00 | 0.0025 | 0.0014 | 0.0001 | 0.0014
750 | .25 | 0.0017 | 0.0010 | 0.0000 | 0.0006
750 | .50 | 0.0011 | 0.0007 | 0.0000 | 0.0000
750 | .75 | 0.0002 | 0.0003 | 0.0000 | −0.0008

Note. See Tables 1 and 2 in the main report for definitions of each effect size index. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom; d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom.

Table B-6 Theoretical variance adjustment to the empirical variance as a function of the correlation (r) between pretest and post-test

r | dhb | dhw | dhw_nonr | db | db_nonr | dg
.00 | 0.0159 | 0.0094 | 0.0007 | 0.0007 | −0.0080 | 0.0003
.25 | 0.0115 | 0.0071 | 0.0028 | 0.0005 | −0.0039 | 0.0003
.50 | 0.0070 | 0.0048 | 0.0048 | 0.0003 | 0.0003 | 0.0003
.75 | 0.0016 | 0.0019 | 0.0071 | 0.0002 | 0.0054 | 0.0005

Note. d_b_nonr_= Becker’s standardized mean difference without including the correlation factor 2(1 − r). d_hw_nonr_=Hedges’s standardized mean difference using the within-study degrees of freedom without including the correlation factor 2(1 − r). See main report, Tables 1 and 2 for definitions of the other ES indexes.

Table B-7 Bias of the ES indexes as a function of sample size (n) and the correlation (r) between pretest and post-test

n | r | d_hb_ | d_hw_ | d_b_ | d_g_ | d_s1_ | d_s2_ | d_s3_
50 | .00 | 0.0042 | −0.1492 | −0.0004 | −0.1467 | 0.0037 | 0.0038 | −0.1191
50 | .25 | 0.0041 | −0.149 | 0.0000 | −0.0927 | 0.0033 | 0.0041 | −0.1143
50 | .50 | 0.0036 | −0.1487 | −0.0002 | −0.0006 | 0.0025 | 0.0045 | −0.0977
50 | .75 | 0.0041 | −0.1473 | 0.0003 | 0.2906 | 0.0029 | 0.0066 | −0.0527
75 | .00 | 0.0022 | −0.1485 | −0.0003 | −0.1464 | 0.0022 | 0.0023 | −0.1288
75 | .25 | 0.0028 | −0.1481 | −0.0003 | −0.0917 | 0.0022 | 0.0028 | −0.1230
75 | .50 | 0.0023 | −0.1479 | 0.0001 | −0.0001 | 0.0018 | 0.0031 | −0.1059
75 | .75 | 0.0026 | −0.1471 | 0.0001 | 0.2902 | 0.0018 | 0.0042 | −0.0590
100 | .00 | 0.0020 | −0.1477 | 0.0002 | −0.1463 | 0.0021 | 0.0021 | −0.1330
100 | .25 | 0.0023 | −0.1475 | 0.0002 | −0.0920 | 0.0019 | 0.0023 | −0.1274
100 | .50 | 0.0017 | −0.1475 | 0.0001 | 0.0000 | 0.0013 | 0.0023 | −0.1099
100 | .75 | 0.0018 | −0.1470 | 0.0000 | 0.2903 | 0.0012 | 0.0031 | −0.0621
250 | .00 | 0.0007 | −0.1470 | 0.0001 | −0.1466 | 0.0007 | 0.0007 | −0.1412
250 | .25 | 0.0010 | −0.1467 | 0.0005 | −0.0916 | 0.0010 | 0.0012 | −0.1354
250 | .50 | 0.0006 | −0.1470 | −0.0003 | −0.0002 | 0.0003 | 0.0007 | −0.1173
250 | .75 | 0.0007 | −0.1468 | −0.0003 | 0.2908 | 0.0003 | 0.0011 | −0.0676
500 | .00 | 0.0000 | −0.1468 | 0.0002 | −0.1464 | 0.0003 | 0.0003 | −0.1441
500 | .25 | 0.0004 | −0.1466 | 0.0002 | −0.0916 | 0.0004 | 0.0005 | −0.1381
500 | .50 | 0.0005 | −0.1467 | −0.0002 | 0.0004 | 0.0002 | 0.0004 | −0.1194
500 | .75 | 0.0005 | −0.1466 | −0.0003 | 0.2905 | 0.0002 | 0.0005 | −0.0693
750 | .00 | 0.0002 | −0.1466 | 0.0001 | −0.1464 | 0.0003 | 0.0003 | −0.1447
750 | .25 | 0.0005 | −0.1466 | −0.0001 | −0.0917 | 0.0003 | 0.0003 | −0.1389
750 | .50 | 0.0003 | −0.1466 | 0.0000 | −0.0002 | 0.0002 | 0.0003 | −0.1204
750 | .75 | 0.0004 | −0.1464 | 0.0001 | 0.2904 | 0.0003 | 0.0005 | −0.0700

Note. See Tables 1 and 2 in the main report for definitions of each effect size index. Bias is defined as the M difference between the estimate of the ES and the parametric value. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom. d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom. d_s1_=Standardized mean difference proposed by Shadish (See Table 2, No. 10). d_s2_=Standardized mean difference proposed by Shadish using the standard deviation from ANOVA results (See Table 2, No. 11). d_s3_=Standardized mean difference proposed by Shadish using the standard deviation from ANCOVA results (See Table 2, No. 12).

Table B-8 Bias of the ES indexes as a function of the correlation (r) between pretest and post-test

r | d_hb_ | d_hw_ | d_b_ | d_g_ | d_s1_ | d_s2_ | d_s3_
.00 | 0.0016 | −0.1476 | 0.0000 | −0.1465 | 0.0016 | 0.0016 | −0.1352
.25 | 0.0019 | −0.1474 | 0.0001 | −0.0919 | 0.0015 | 0.0019 | −0.1295
.50 | 0.0015 | −0.1474 | −0.0001 | −0.0001 | 0.0011 | 0.0019 | −0.1118
.75 | 0.0017 | −0.1469 | 0.0000 | 0.2905 | 0.0011 | 0.0027 | −0.0635

Note. See Tables 1 and 2 in the main report for definitions of each ES index. Bias is defined as the M difference between the estimate of the ES and the parametric value. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom. d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom. d_s1_=Standardized mean difference proposed by Shadish (See Table 2, No. 10). d_s2_=Standardized mean difference proposed by Shadish using the standard deviation from ANOVA results (See Table 2, No. 11). d_s3_=Standardized mean difference proposed by Shadish using the standard deviation from ANCOVA results (See Table 2, No. 12). d_tch_=the standardized mean difference in change-score metric from t_d_. d_tra_=standardized mean difference in raw-score metric form t_d_.

Table B-9 Efficiency of the ES indexes as a function of sample size (n) and the correlation (r) between pretest and post-test

n | r | d_hb_ | d_hw_ | d_b_ | d_g_ | d_s1_ | d_s2_ | d_s3_
50 | .00 | 0.0027 | 0.0006 | 0.0027 | 0.0013 | 0.0013 | 0.0013 | 0.0016
50 | .25 | 0.0028 | 0.0007 | 0.0027 | 0.0017 | 0.0014 | 0.0014 | 0.0016
50 | .50 | 0.0026 | 0.0008 | 0.0027 | 0.0026 | 0.0017 | 0.0017 | 0.0015
50 | .75 | 0.0027 | 0.0011 | 0.0027 | 0.0068 | 0.0022 | 0.0022 | 0.0017
75 | .00 | 0.0018 | 0.0004 | 0.0017 | 0.0009 | 0.0009 | 0.0009 | 0.0010
75 | .25 | 0.0018 | 0.0004 | 0.0017 | 0.0011 | 0.0009 | 0.0009 | 0.0010
75 | .50 | 0.0017 | 0.0005 | 0.0017 | 0.0017 | 0.0011 | 0.0011 | 0.0009
75 | .75 | 0.0018 | 0.0007 | 0.0018 | 0.0044 | 0.0014 | 0.0014 | 0.0010
100 | .00 | 0.0013 | 0.0003 | 0.0013 | 0.0006 | 0.0006 | 0.0006 | 0.0007
100 | .25 | 0.0013 | 0.0003 | 0.0013 | 0.0009 | 0.0007 | 0.0007 | 0.0007
100 | .50 | 0.0013 | 0.0004 | 0.0013 | 0.0013 | 0.0008 | 0.0008 | 0.0007
100 | .75 | 0.0013 | 0.0005 | 0.0013 | 0.0033 | 0.0010 | 0.0010 | 0.0007
250 | .00 | 0.0005 | 0.0001 | 0.0005 | 0.0003 | 0.0003 | 0.0003 | 0.0003
250 | .25 | 0.0005 | 0.0001 | 0.0005 | 0.0003 | 0.0003 | 0.0003 | 0.0003
250 | .50 | 0.0005 | 0.0002 | 0.0005 | 0.0005 | 0.0003 | 0.0003 | 0.0003
250 | .75 | 0.0005 | 0.0002 | 0.0005 | 0.0013 | 0.0004 | 0.0004 | 0.0003
500 | .00 | 0.0003 | 0.0001 | 0.0003 | 0.0001 | 0.0001 | 0.0001 | 0.0001
500 | .25 | 0.0002 | 0.0001 | 0.0003 | 0.0002 | 0.0001 | 0.0001 | 0.0001
500 | .50 | 0.0003 | 0.0001 | 0.0002 | 0.0003 | 0.0002 | 0.0002 | 0.0001
500 | .75 | 0.0002 | 0.0001 | 0.0003 | 0.0006 | 0.0002 | 0.0002 | 0.0001
750 | .00 | 0.0002 | 0.0000 | 0.0002 | 0.0001 | 0.0001 | 0.0001 | 0.0001
750 | .25 | 0.0002 | 0.0000 | 0.0002 | 0.0001 | 0.0001 | 0.0001 | 0.0001
750 | .50 | 0.0002 | 0.0001 | 0.0002 | 0.0002 | 0.0001 | 0.0001 | 0.0001
750 | .75 | 0.0002 | 0.0001 | 0.0002 | 0.0004 | 0.0001 | 0.0001 | 0.0001

Note. See Tables 1 and 2 in the main report for definitions of each ES index. Bias is defined as the M difference between the estimate of the ES and the parametric value. db=Becker’s standardized mean difference; dg=Gibbons’s standardized mean difference. dhb=Hedges’s standardized mean difference using the between-studies degrees of freedom. dhw=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom. ds1=Standardized mean difference proposed by Shadish (See Table 2, No. 10). ds2=Standardized mean difference proposed by Shadish using the standard deviation from ANOVA results (See Table 2, No. 11). ds3=Standardized mean difference proposed by Shadish using the standard deviation from ANCOVA results (See Table 2, No. 12).

Table B-10 Mean efficiency for the ES indexes as a function of the correlation (r) between pretest and post-test

r | d_hb_ | d_hw_ | d_b_ | d_g_ | d_s1_ | d_s2_ | d_s3_
.00 | 0.0011 | 0.0003 | 0.0011 | 0.0006 | 0.0006 | 0.0006 | 0.0006
.25 | 0.0011 | 0.0003 | 0.0011 | 0.0007 | 0.0006 | 0.0006 | 0.0006
.50 | 0.0011 | 0.0004 | 0.0011 | 0.0011 | 0.0007 | 0.0007 | 0.0006
.75 | 0.0011 | 0.0005 | 0.0011 | 0.0028 | 0.0009 | 0.0009 | 0.0007

Note. See Tables 1 and 2 in the main report for definitions of each ES index. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom. d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom. d_s1_=Standardized mean difference proposed by Shadish (See Table 2, No. 10). d_s2_=Standardized mean difference proposed by Shadish using the standard deviation from ANOVA results (See Table 2, No. 11). d_s3_=Standardized mean difference proposed by Shadish using the standard deviation from ANCOVA results (See Table 2, No. 12).

Table B-11 Theoretical variance adjustment to the empirical variance for those formulas that consider the ES a sum of two ES or as a total ES

n | r | d_hb_ | d_hw_ | d_hw_total_ | d_b_ | d_b_total_ | d_g_ | d_g_total_ | d_s1_ | d_s3_
50 | .00 | 0.0395 | 0.2800 | 0.0408 | 0.2581 | 0.0395 | 0.2367 | 0.0202 | 0.0409 | 0.0400
50 | .25 | 0.0394 | 0.2697 | 0.0408 | 0.2592 | 0.0395 | 0.2503 | 0.0271 | 0.0408 | 0.0401
50 | .50 | 0.0395 | 0.2603 | 0.0407 | 0.2600 | 0.0394 | 0.2601 | 0.0412 | 0.0405 | 0.0402
50 | .75 | 0.0395 | 0.2489 | 0.0404 | 0.2593 | 0.0395 | 0.2104 | 0.0818 | 0.0400 | 0.0402
75 | .00 | 0.0262 | 0.2637 | 0.0270 | 0.2574 | 0.0262 | 0.2358 | 0.0133 | 0.0271 | 0.0266
75 | .25 | 0.0262 | 0.2550 | 0.0270 | 0.2549 | 0.0262 | 0.2468 | 0.0178 | 0.0270 | 0.0266
75 | .50 | 0.0262 | 0.2470 | 0.0269 | 0.2536 | 0.0262 | 0.2535 | 0.0269 | 0.0268 | 0.0266
75 | .75 | 0.0262 | 0.2414 | 0.0268 | 0.2557 | 0.0262 | 0.2095 | 0.0532 | 0.0265 | 0.0267
100 | .00 | 0.0196 | 0.2549 | 0.0202 | 0.2556 | 0.0196 | 0.2340 | 0.0099 | 0.0202 | 0.0199
100 | .25 | 0.0196 | 0.2482 | 0.0202 | 0.2534 | 0.0196 | 0.2453 | 0.0132 | 0.0202 | 0.0199
100 | .50 | 0.0196 | 0.2426 | 0.0201 | 0.2534 | 0.0195 | 0.2532 | 0.0199 | 0.0200 | 0.0199
100 | .75 | 0.0196 | 0.2388 | 0.0200 | 0.2549 | 0.0196 | 0.2092 | 0.0394 | 0.0198 | 0.0200
250 | .00 | 0.0078 | 0.2386 | 0.0080 | 0.2520 | 0.0078 | 0.2304 | 0.0039 | 0.0080 | 0.0079
250 | .25 | 0.0078 | 0.2364 | 0.0080 | 0.2516 | 0.0078 | 0.2433 | 0.0052 | 0.0080 | 0.0079
250 | .50 | 0.0078 | 0.2339 | 0.0080 | 0.2511 | 0.0078 | 0.2511 | 0.0078 | 0.0080 | 0.0079
250 | .75 | 0.0078 | 0.2320 | 0.0080 | 0.2513 | 0.0078 | 0.2072 | 0.0155 | 0.0079 | 0.0079
500 | .00 | 0.0039 | 0.2337 | 0.0040 | 0.2511 | 0.0039 | 0.2297 | 0.0019 | 0.0040 | 0.0039
500 | .25 | 0.0039 | 0.2331 | 0.0040 | 0.2514 | 0.0039 | 0.2431 | 0.0026 | 0.0040 | 0.0039
500 | .50 | 0.0039 | 0.2316 | 0.0040 | 0.2510 | 0.0039 | 0.2510 | 0.0039 | 0.0040 | 0.0040
500 | .75 | 0.0039 | 0.2302 | 0.0040 | 0.2506 | 0.0039 | 0.2072 | 0.0077 | 0.0039 | 0.0040
750 | .00 | 0.0026 | 0.2317 | 0.0027 | 0.2504 | 0.0026 | 0.2290 | 0.0013 | 0.0027 | 0.0026
750 | .25 | 0.0026 | 0.2305 | 0.0027 | 0.2498 | 0.0026 | 0.2415 | 0.0017 | 0.0027 | 0.0026
750 | .50 | 0.0026 | 0.2306 | 0.0027 | 0.2506 | 0.0026 | 0.2506 | 0.0026 | 0.0026 | 0.0026
750 | .75 | 0.0026 | 0.2302 | 0.0026 | 0.2510 | 0.0026 | 0.2077 | 0.0051 | 0.0026 | 0.0026

Note. See the text in the main report for definitions of each ES index. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom. d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom. d_s1_=Standardized mean difference proposed by Shadish (See Table 2, No. 10). d_s3_=Standardized mean difference proposed by Shadish using the standard deviation from ANCOVA results (See Table 2, No. 12). d_tch_=the standardized mean difference in change-score metric from t_d_. d_tra_=standardized mean difference in raw-score metric form t_d_.

Table B-12 Mean of theoretical variance adjustment to the empirical variance as a function of the correlation (r)

r | d_hb_ | d_hw_ | d_hw_total_ | d_b_ | d_b_total_ | d_g_ | d_g_total_ | d_s1_ | d_s3_
.00 | 0.0166 | 0.2504 | 0.0171 | 0.2541 | 0.0166 | 0.2326 | 0.0169 | 0.0172 | 0.0168
.25 | 0.0166 | 0.2455 | 0.0171 | 0.2534 | 0.0166 | 0.2451 | 0.0168 | 0.0171 | 0.0168
.50 | 0.0166 | 0.2410 | 0.0171 | 0.2533 | 0.0166 | 0.2533 | 0.0166 | 0.0170 | 0.0169
.75 | 0.0166 | 0.2369 | 0.0170 | 0.2538 | 0.0166 | 0.2085 | 0.0155 | 0.0168 | 0.0169

Note. See the text in the main report for definitions of each ES index. Bias is defined as the M difference between the estimate of the ES and the parametric value. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hb_=Hedges’s standardized mean difference using the between-studies degrees of freedom. d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom. d_s1_=Standardized mean difference proposed by Shadish (See Table 2, No. 10). d_s3_=Standardized mean difference proposed by Shadish using the standard deviation from ANCOVA results (See Table 2, No. 12). d_tch_=the standardized mean difference in change-score metric from t_d_. d_tra_=standardized mean difference in raw-score metric form t_d_.

Table B-13 Theoretical variance adjustment to the empirical variance for those formulas considering the es as a total value and including or excluding the correlation (r) factor into the equation

n | r | d_hw_total_r_ | d_hw_total_nonr_ | d_b_total_r_ | d_b_total_nonr_ | d_g_total_r_ | d_g_total_nonr_
50 | .00 | 0.0208 | 0.0408 | 0.0195 | 0.0395 | 0.0202 | 0.0402
50 | .25 | 0.0279 | 0.0408 | 0.0266 | 0.0395 | 0.0271 | 0.0400
50 | .50 | 0.0423 | 0.0407 | 0.0411 | 0.0394 | 0.0412 | 0.0396
50 | .75 | 0.0855 | 0.0404 | 0.0845 | 0.0395 | 0.0818 | 0.0368
75 | .00 | 0.0137 | 0.0270 | 0.0129 | 0.0262 | 0.0133 | 0.0266
75 | .25 | 0.0184 | 0.0270 | 0.0176 | 0.0262 | 0.0178 | 0.0265
75 | .50 | 0.0277 | 0.0269 | 0.0269 | 0.0262 | 0.0269 | 0.0262
75 | .75 | 0.0556 | 0.0268 | 0.0550 | 0.0262 | 0.0532 | 0.0244
100 | .00 | 0.0102 | 0.0202 | 0.0096 | 0.0196 | 0.0099 | 0.0199
100 | .25 | 0.0136 | 0.0202 | 0.0130 | 0.0196 | 0.0132 | 0.0198
100 | .50 | 0.0205 | 0.0201 | 0.0199 | 0.0195 | 0.0199 | 0.0195
100 | .75 | 0.0412 | 0.0200 | 0.0408 | 0.0196 | 0.0394 | 0.0182
250 | .00 | 0.0040 | 0.0080 | 0.0038 | 0.0078 | 0.0039 | 0.0079
250 | .25 | 0.0054 | 0.0080 | 0.0051 | 0.0078 | 0.0052 | 0.0079
250 | .50 | 0.0081 | 0.0080 | 0.0078 | 0.0078 | 0.0078 | 0.0078
250 | .75 | 0.0162 | 0.0080 | 0.0160 | 0.0078 | 0.0155 | 0.0073
500 | .00 | 0.0020 | 0.0040 | 0.0019 | 0.0039 | 0.0019 | 0.0039
500 | .25 | 0.0027 | 0.0040 | 0.0025 | 0.0039 | 0.0026 | 0.0039
500 | .50 | 0.0040 | 0.0040 | 0.0039 | 0.0039 | 0.0039 | 0.0039
500 | .75 | 0.0080 | 0.0040 | 0.0079 | 0.0039 | 0.0077 | 0.0036
750 | .00 | 0.0013 | 0.0027 | 0.0013 | 0.0026 | 0.0013 | 0.0026
750 | .25 | 0.0018 | 0.0027 | 0.0017 | 0.0026 | 0.0017 | 0.0026
750 | .50 | 0.0027 | 0.0027 | 0.0026 | 0.0026 | 0.0026 | 0.0026
750 | .75 | 0.0053 | 0.0026 | 0.0053 | 0.0026 | 0.0051 | 0.0024

Note. See the text in the main report for definitions of each ES index. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom.

Table B-14 Mean of theoretical variance adjustment to the empirical variance as a function of the correlation

r | d_hw_total_r_ | d_hw_total_nonr_ | d_b_total_r_ | d_b_total_nonr_ | d_g_total_r_ | d_g_total_nonr_
.00 | 0.0087 | 0.0171 | 0.0082 | 0.0166 | 0.0084 | 0.0169
.25 | 0.0116 | 0.0171 | 0.0111 | 0.0166 | 0.0113 | 0.0168
.50 | 0.0176 | 0.0171 | 0.0170 | 0.0166 | 0.0171 | 0.0166
.75 | 0.0353 | 0.0170 | 0.0349 | 0.0166 | 0.0338 | 0.0155

Note. See the text in the main report for definitions of each ES index. Bias is defined as the M difference between the estimate of the ES and the parametric value. d_b_=Becker’s standardized mean difference; d_g_=Gibbons’s standardized mean difference. d_hw_=Huedo-Medina and Johnson’s standardized mean difference using the within-study degrees of freedom.