# Bias and Efficiency Results for Standardized and Raw Mean Differences (Specific Aim 1)

This appendix contains the bias and efficiency results in relation to the two different effect sizes metrics, unstandardized (UMD) versus standardized (SMD) mean differences, with results divided by simulation conditions that related either to bias, efficiency, or both.

Table A-1 Bias of the effect sizes metrics as a function of deviations from normality (skewness/kurtosis), the parametric effect size, and sample size, under fixed-effects assumptions (i.e., τ=0)

Skewness/Kurtosis | δ | n | SMD | UMD
0/3 | 0.25 | 30 | −0.0003 | 0.0210
0/3 | 0.25 | 50 | −0.0005 | 0.0239
0/3 | 0.25 | 80 | −0.0003 | 0.0261
0/3
0/3 | 0.50 | 30 | −0.0003 | 0.0284
0/3 | 0.50 | 50 | −0.0005 | 0.0309
0/3 | 0.50 | 80 | −0.0003 | 0.0333
0/3
0/3 | 0.80 | 30 | −0.0003 | 0.0078
0/3 | 0.80 | 50 | −0.0005 | 0.0099
0/3 | 0.80 | 80 | −0.0003 | 0.0122
0.75/0 | 0.25 | 30 | −0.1021 | 0.1389
0.75/0 | 0.25 | 50 | −0.1035 | 0.1322
0.75/0 | 0.25 | 80 | −0.1043 | 0.1346
0.75/0
0.75/0 | 0.50 | 30 | −0.1021 | 0.1605
0.75/0 | 0.50 | 50 | −0.1035 | 0.1639
0.75/0 | 0.50 | 80 | −0.1043 | 0.1667
0.75/0
0.75/0 | 0.80 | 30 | −0.1021 | 0.1923
0.75/0 | 0.80 | 50 | −0.1035 | 0.1955
0.75/0 | 0.80 | 80 | −0.1043 | 0.1985
1.75/3.75 | 0.25 | 30 | 0.2001 | 0.2369
1.75/3.75 | 0.25 | 50 | −0.2104 | 0.2404
1.75/3.75 | 0.25 | 80 | −0.2002 | 0.2431
1.75/3.75
1.75/3.75 | 0.50 | 30 | 0.2001 | 0.2925
1.75/3.75 | 0.50 | 50 | −0.2104 | 0.2967
1.75/3.75 | 0.50 | 80 | −0.2002 | 0.3001
1.75/3.75
1.75/3.75 | 0.80 | 30 | 0.2001 | 0.3767
1.75/3.75 | 0.80 | 50 | −0.2104 | 0.3812
1.75/3.75 | 0.80 | 80 | −0.2002 | 0.3848

Table A-2 Bias of the effect sizes metrics under random-effects assumptions (τ^2^ = 0.08)

Skewness/Kurtosis | δ | n | SMD | UMD
0/3 | 0.25 | 30 | 0.0001 | 0.0175
0/3 | 0.25 | 50 | 0.0019 | 0.0257
0/3 | 0.25 | 80 | 0.0017 | 0.0279
0/3
0/3 | 0.50 | 30 | 0.0001 | 0.0259
0/3 | 0.50 | 50 | 0.0019 | 0.0334
0/3 | 0.50 | 80 | 0.0017 | 0.0353
0/3
0/3 | 0.80 | 30 | 0.0001 | 0.0066
0/3 | 0.80 | 50 | 0.0019 | 0.0131
0/3 | 0.80 | 80 | 0.0017 | 0.0146
0.75/0 | 0.25 | 30 | 0.1001 | 0.1750
0.75/0 | 0.25 | 50 | 0.1019 | 0.1839
0.75/0 | 0.25 | 80 | 0.1017 | 0.1864
0.75/0
0.75/0 | 0.50 | 30 | 0.1001 | 0.1573
0.75/0 | 0.50 | 50 | 0.1019 | 0.1663
0.75/0 | 0.50 | 80 | 0.1017 | 0.1688
0.75/0
0.75/0 | 0.80 | 30 | 0.1001 | 0.1907
0.75/0 | 0.80 | 50 | 0.1019 | 0.1991
0.75/0 | 0.80 | 80 | 0.1017 | 0.2012
1.75/3.75 | 0.25 | 30 | 0.1001 | 0.1325
1.75/3.75 | 0.25 | 50 | 0.1019 | 0.1421
1.75/3.75 | 0.25 | 80 | 0.1017 | 0.1448
1.75/3.75
1.75/3.75 | 0.50 | 30 | 0.1001 | 0.2887
1.75/3.75 | 0.50 | 50 | 0.1019 | 0.2992
1.75/3.75 | 0.50 | 80 | 0.1017 | 0.3023
1.75/3.75
1.75/3.75 | 0.80 | 30 | 0.1001 | 0.3748
1.75/3.75 | 0.80 | 50 | 0.1019 | 0.3851
1.75/3.75 | 0.80 | 80 | 0.1017 | 0.3879

Table A-3 Bias of the effect sizes metrics under random-effects assumptions (τ^2^ = 0.32)

Skewness/Kurtosis | δ | n | SMD | UMD
0/3 | 0.25 | 30 | 0.0001 | 0.0175
0/3 | 0.25 | 50 | 0.0019 | 0.0257
0/3 | 0.25 | 80 | 0.0017 | 0.0279
0/3
0/3 | 0.50 | 30 | 0.0001 | 0.0259
0/3 | 0.50 | 50 | 0.0019 | 0.0334
0/3 | 0.50 | 80 | 0.0017 | 0.0353
0/3
0/3 | 0.80 | 30 | 0.0001 | 0.0066
0/3 | 0.80 | 50 | 0.0019 | 0.0131
0/3 | 0.80 | 80 | 0.0017 | 0.0146
0.75/0 | 0.25 | 30 | 0.1001 | 0.1750
0.75/0 | 0.25 | 50 | 0.1019 | 0.1839
0.75/0 | 0.25 | 80 | 0.1017 | 0.1864
0.75/0
0.75/0 | 0.50 | 30 | 0.1001 | 0.1573
0.75/0 | 0.50 | 50 | 0.1019 | 0.1663
0.75/0 | 0.50 | 80 | 0.1017 | 0.1688
0.75/0
0.75/0 | 0.80 | 30 | 0.1001 | 0.1907
0.75/0 | 0.80 | 50 | 0.1019 | 0.1991
0.75/0 | 0.80 | 80 | 0.1017 | 0.2012
1.75/3.75 | 0.25 | 30 | 0.1001 | 0.1325
1.75/3.75 | 0.25 | 50 | 0.1019 | 0.1421
1.75/3.75 | 0.25 | 80 | 0.1017 | 0.1448
1.75/3.75
1.75/3.75 | 0.50 | 30 | 0.1001 | 0.2887
1.75/3.75 | 0.50 | 50 | 0.1019 | 0.2992
1.75/3.75 | 0.50 | 80 | 0.1017 | 0.3023
1.75/3.75
1.75/3.75 | 0.80 | 30 | 0.1001 | 0.3748
1.75/3.75 | 0.80 | 50 | 0.1019 | 0.3851
1.75/3.75 | 0.80 | 80 | 0.1017 | 0.3879

Table A-4 Bias of the effect sizes metrics as a function of deviations from normality (skewness/kurtosis), variance equality between the two compared groups, and between-studies variance

Skewness/Kurtosis | Ratio of variances (E:C) | τ^2^ | SMD | UMD
0/3 | 1:1 | 0 | 0.0001 | 0.0175
0/3 | 1:1 | 0.08 | 0.0019 | 0.0257
0/3 | 1:1 | 0.32 | 0.0017 | 0.0279
0/3
0/3 | 1:2 | 0 | 0.0001 | 0.0259
0/3 | 1:2 | 0.08 | 0.0019 | 0.0334
0/3 | 1:2 | 0.32 | 0.0017 | 0.0353
0/3
0/3 | 4:1 | 0 | 0.0001 | 0.0366
0/3 | 4:1 | 0.08 | 0.0019 | 0.0431
0/3 | 4:1 | 0.32 | 0.0017 | 0.0546
0.75/0 | 1:1 | 0 | 0.1001 | 0.1750
0.75/0 | 1:1 | 0.08 | 0.1019 | 0.1839
0.75/0 | 1:1 | 0.32 | 0.1017 | 0.1864
0.75/0
0.75/0 | 1:2 | 0 | 0.2101 | 0.3573
0.75/0 | 1:2 | 0.08 | 0.2119 | 0.3663
0.75/0 | 1:2 | 0.32 | 0.2117 | 0.3688
0.75/0
0.75/0 | 4:1 | 0 | 0.3101 | 0.4907
0.75/0 | 4:1 | 0.08 | 0.3219 | 0.4991
0.75/0 | 4:1 | 0.32 | 0.3317 | 0.4012
1.75/3.75 | 1:1 | 0 | 0.1001 | 0.1325
1.75/3.75 | 1:1 | 0.08 | 0.1019 | 0.1421
1.75/3.75 | 1:1 | 0.32 | 0.1017 | 0.1448
1.75/3.75
1.75/3.75 | 1:2 | 0 | 0.3101 | 0.4887
1.75/3.75 | 1:2 | 0.08 | 0.3119 | 0.4992
1.75/3.75 | 1:2 | 0.32 | 0.3117 | 0.4023
1.75/3.75
1.75/3.75 | 4:1 | 0 | 0.3801 | 0.5748
1.75/3.75 | 4:1 | 0.08 | 0.3819 | 0.5851
1.75/3.75 | 4:1 | 0.32 | 0.3917 | 0.5879

Note. E:C=Variance of experimental group relative to variance of control group.

Table A-5 Efficiency of the effect sizes metrics under fixed-effects assumptions (τ2 = 0)

Skewness/Kurtosis | δ | n | SMD | UMD
0/3 | 0.25 | 30 | 0.1104 | 0.1108
0/3 | 0.25 | 50 | 0.0492 | 0.0500
0/3 | 0.25 | 80 | 0.0276 | 0.0281
0/3
0/3 | 0.50 | 30 | 0.1104 | 0.1109
0/3 | 0.50 | 50 | 0.0492 | 0.0500
0/3 | 0.50 | 80 | 0.0276 | 0.0282
0/3
0/3 | 0.80 | 30 | 0.1104 | 0.1106
0/3 | 0.80 | 50 | 0.0492 | 0.0499
0/3 | 0.80 | 80 | 0.0276 | 0.0281
0.75/0 | 0.25 | 30 | 0.1868 | 0.2117
0.75/0 | 0.25 | 50 | 0.0718 | 0.1504
0.75/0 | 0.25 | 80 | 0.0690 | 0.1284
0.75/0
0.75/0 | 0.50 | 30 | 0.1868 | 0.2131
0.75/0 | 0.50 | 50 | 0.0718 | 0.1510
0.75/0 | 0.50 | 80 | 0.0690 | 0.1287
0.75/0
0.75/0 | 0.80 | 30 | 0.1868 | 0.2137
0.75/0 | 0.80 | 50 | 0.0718 | 0.1513
0.75/0 | 0.80 | 80 | 0.0690 | 0.1289
1.75/3.75 | 0.25 | 30 | 0.2286 | 0.3126
1.75/3.75 | 0.25 | 50 | 0.1568 | 0.2508
1.75/3.75 | 0.25 | 80 | 0.1318 | 0.2286
1.75/3.75
1.75/3.75 | 0.50 | 30 | 0.2286 | 0.3157
1.75/3.75 | 0.50 | 50 | 0.1568 | 0.2522
1.75/3.75 | 0.50 | 80 | 0.1318 | 0.2294
1.75/3.75
1.75/3.75 | 0.80 | 30 | 0.2286 | 0.3177
1.75/3.75 | 0.80 | 50 | 0.1568 | 0.2531
1.75/3.75 | 0.80 | 80 | 0.1318 | 0.2299

Table A-6 Efficiency of effect size indexes under random-effects assumptions (τ^2^ = 0.08)

Skewness/Kurtosis | δ | n | SMD | UMD
0/3 | 0.25 | 30 | 0.1104 | 0.1118
0/3 | 0.25 | 50 | 0.0492 | 0.0505
0/3 | 0.25 | 80 | 0.0276 | 0.0284
0/3
0/3 | 0.50 | 30 | 0.1104 | 0.1117
0/3 | 0.50 | 50 | 0.0492 | 0.0504
0/3 | 0.50 | 80 | 0.0276 | 0.0284
0/3
0/3 | 0.80 | 30 | 0.1104 | 0.1112
0/3 | 0.80 | 50 | 0.0492 | 0.0502
0/3 | 0.80 | 80 | 0.0276 | 0.0283
0.75/0 | 0.25 | 30 | 0.1867 | 0.2127
0.75/0 | 0.25 | 50 | 0.0718 | 0.1509
0.75/0 | 0.25 | 80 | 0.0690 | 0.1286
0.75/0
0.75/0 | 0.50 | 30 | 0.1867 | 0.2139
0.75/0 | 0.50 | 50 | 0.0718 | 0.1514
0.75/0 | 0.50 | 80 | 0.0690 | 0.1289
0.75/0
0.75/0 | 0.80 | 30 | 0.1867 | 0.2143
0.75/0 | 0.80 | 50 | 0.0718 | 0.1516
0.75/0 | 0.80 | 80 | 0.0690 | 0.1290
1.75/3.75 | 0.25 | 30 | 0.2286 | 0.3136
1.75/3.75 | 0.25 | 50 | 0.1568 | 0.2513
1.75/3.75 | 0.25 | 80 | 0.1318 | 0.2289
1.75/3.75
1.75/3.75 | 0.50 | 30 | 0.2286 | 0.3165
1.75/3.75 | 0.50 | 50 | 0.1568 | 0.2526
1.75/3.75 | 0.50 | 80 | 0.1318 | 0.2296
1.75/3.75
1.75/3.75 | 0.80 | 30 | 0.2286 | 0.3183
1.75/3.75 | 0.80 | 50 | 0.1568 | 0.2534
1.75/3.75 | 0.80 | 80 | 0.1318 | 0.2301

Table A-7 Efficiency of the effect sizes indexes under random effects assumptions (τ^2^ = 0.32)

Skewness/Kurtosis | δ | n | SMD | UMD
0/3 | 0.25 | 30 | 0.0552 | 0.1149
0/3 | 0.25 | 50 | 0.0246 | 0.0519
0/3 | 0.25 | 80 | 0.0138 | 0.0292
0/3
0/3 | 0.50 | 30 | 0.0552 | 0.1143
0/3 | 0.50 | 50 | 0.0246 | 0.0516
0/3 | 0.50 | 80 | 0.0138 | 0.0290
0/3
0/3 | 0.80 | 30 | 0.0552 | 0.1132
0/3 | 0.80 | 50 | 0.0246 | 0.0511
0/3 | 0.80 | 80 | 0.0138 | 0.0288
0.75/0 | 0.25 | 30 | 0.0983 | 0.2158
0.75/0 | 0.25 | 50 | 0.0759 | 0.1523
0.75/0 | 0.25 | 80 | 0.0445 | 0.1294
0.75/0
0.75/0 | 0.50 | 30 | 0.0983 | 0.2165
0.75/0 | 0.50 | 50 | 0.0759 | 0.1526
0.75/0 | 0.50 | 80 | 0.0445 | 0.1296
0.75/0
0.75/0 | 0.80 | 30 | 0.0983 | 0.2162
0.75/0 | 0.80 | 50 | 0.0759 | 0.1525
0.75/0 | 0.80 | 80 | 0.0445 | 0.1295
1.75/3.75 | 0.25 | 30 | 0.1642 | 0.3167
1.75/3.75 | 0.25 | 50 | 0.1284 | 0.2527
1.75/3.75 | 0.25 | 80 | 0.1159 | 0.2297
1.75/3.75
1.75/3.75 | 0.50 | 30 | 0.1642 | 0.3191
1.75/3.75 | 0.50 | 50 | 0.1284 | 0.2538
1.75/3.75 | 0.50 | 80 | 0.1159 | 0.2303
1.75/3.75
1.75/3.75 | 0.80 | 30 | 0.1642 | 0.3202
1.75/3.75 | 0.80 | 50 | 0.1284 | 0.2543
1.75/3.75 | 0.80 | 80 | 0.1159 | 0.2306

Table A-8 Efficiency of the effect sizes metrics as a function of deviations from normality, variance equality between the two compared groups, and between-studies variance

Skewness/Kurtosis | Ratio of variances (E:C) | τ^2^ | SMD | UMD
0/3 | 1:1 | 0 | 0.0001 | 0.0175
0/3 | 1:1 | 0.08 | 0.0019 | 0.0257
0/3 | 1:1 | 0.32 | 0.0017 | 0.0279
0/3
0/3 | 1:2 | 0 | 0.0001 | 0.0259
0/3 | 1:2 | 0.08 | 0.0019 | 0.0334
0/3 | 1:2 | 0.32 | 0.0017 | 0.0353
0/3
0/3 | 4:1 | 0 | 0.0001 | 0.0066
0/3 | 4:1 | 0.08 | 0.0019 | 0.0131
0/3 | 4:1 | 0.32 | 0.0017 | 0.0146
0.75/0 | 1:1 | 0 | 0.0111 | 0.0750
0.75/0 | 1:1 | 0.08 | 0.0119 | 0.0839
0.75/0 | 1:1 | 0.32 | 0.0117 | 0.0864
0.75/0
0.75/0 | 1:2 | 0 | 0.0101 | 0.1573
0.75/0 | 1:2 | 0.08 | 0.0119 | 0.1663
0.75/0 | 1:2 | 0.32 | 0.0117 | 0.1688
0.75/0
0.75/0 | 4:1 | 0 | 0.0101 | 0.1907
0.75/0 | 4:1 | 0.08 | 0.0119 | 0.1991
0.75/0 | 4:1 | 0.32 | 0.0117 | 0.2012
1.75/3.75 | 1:1 | 0 | 0.0180 | 0.1325
1.75/3.75 | 1:1 | 0.08 | 0.0216 | 0.1421
1.75/3.75 | 1:1 | 0.32 | 0.0225 | 0.1448
1.75/3.75
1.75/3.75 | 1:2 | 0 | 0.0180 | 0.2887
1.75/3.75 | 1:2 | 0.08 | 0.0216 | 0.2992
1.75/3.75 | 1:2 | 0.32 | 0.0225 | 0.3023
1.75/3.75
1.75/3.75 | 4:1 | 0 | 0.0180 | 0.3748
1.75/3.75 | 4:1 | 0.08 | 0.0216 | 0.3851
1.75/3.75 | 4:1 | 0.32 | 0.0225 | 0.3879

Note. E:C=Variance of experimental group relative to variance of control group.