# Results

For the three CERs in this exploratory study, we identified a total of 40 RCTs that fulfilled our inclusion criteria: trials published in 2005 or later that reported the index outcome and for which we were able to identify trial registration. Twenty-four of these trials were included in the CER on oral hypoglycemic agents,19 14 on lipid-modifying agents24 and 12 on treatments to prevent fractures.26

Table 6 summarizes the characteristics of the RCTs for the index outcomes of the three CERs. Registered trials variably reported trial registration numbers in the publications (28.6, 66.7, and 75.0 percent for the CERs on lipid modifying agents, fracture prevention drugs, and oral hypoglycemic agents, respectively). The majority of registered studies were listed in ClinicalTrials.gov, although this varied across the three CERs. The percentage of trials with results posted in the registry also varied (8.3, 14.3, and 62.5 percent for fracture prevention drugs, lipid modifying agents, and oral hypoglycemic agents, respectively). Of trials published from September, 2008 forward (when results reporting was mandated for some trials within ClinicalTrials.gov), 81 percent of the hypoglycemic agent trials and 100 percent of the lipid modifying agent trials were registered.

Table 6 Characteristics of trials that reported the index outcomes

CER | Index Outcome | Total Unique RCTs in the CER (n) | RCTs Published 2005 to January 2012 (n) | Registered Trials (n [% 2005-January 4, 2012;^a^ % all years^b^]) | Trials with Registry Number Reported in the Publication n (%) | Trials Included in ClinicalTrials.gov (n [% of Trials Registered]) | Trials Included in ISRCTN Registry (n [% of Trials Registered]) | Trials Listed in Registries Not in ICTRP (n [% of Trials Registered]) | Trials with Results Reported in the Registry (n [% of Trials Registered; % Published September 2008 to January 2012])
Oral Diabetes Medications for Adults With Type 2 Diabetes19 | A1c | 98 | 59 | 24 (40.7; 24.5) | 18/24 (75) | 23 (95.8) | 0 (0.0) | 1 (4.2) UMIN Clinical Trials Registry^c^ | 15 (62.5; 81.3)
Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis26 | Fracture reduction, including both vertebral and extremity, hip, and other sites | 177 | 29 | 12 (41.4; 6.8) | 8/12 (66.7) | 8 (66.7) | 2 (16.7) | 2 (16.7) Australia New Zealand Clinical Trials Registry | 1 (8.3; NA)
Comparative Effectiveness of Lipid-Modifying Agents24 | All-cause mortality | 24 | 19 | 14 (73.7; 58.3) | 4/14 (28.6) | 11 (78.6) | 2 (14.3) | 1 (7.1%) Cochrane Renal Group^c^ | 2 (14.3; 100.0)

Abbreviations: A1c, hemoglobin A1c; CER, comparative effectiveness review; ICTRP, International Clinical Trials Registry Platform; ISRCTN, International Standard Randomized Controlled Trial Number; n, number; RCTs, randomized controlled trial

a Percentage of trials reporting the index outcome published in or after 2005 that were registered.

b Percentage of all trials reporting the index outcome that were registered.

c Two publications indicated trial registration in registries not contained within the International Clinical Trials Registry Platform.

We contacted the authors of trials reporting the index outcome when there was no indication of study registration in the publication. In total we attempted to contact 79 corresponding authors by email; 12 email addresses were no longer valid. A total of 26 authors responded (39 percent of authors with valid addresses), and of those, 23 authors indicated that their trials were not registered and three authors provided trial registry numbers.

## Frequency and Characterization of Selective Outcome Reporting and Selective Analysis Reporting

Tables 7–10 summarize our findings on SOR and SAR, including our three consensus judgments on the presence of SOR and SAR as defined previously in Table 3. Additional details on the studies included in our analyses are provided in Appendix tables B1 to B16.

Table 7 Selective outcome reporting and selective analysis reporting for hemoglobin A1c (n=24) based on the publication only (judgment #1)

No/Yes | Outcomes in Trials Related to A1c | | | | | Discrepancies Between Publication Methods and Results
No/Yes | Change in A1c From Baseline | Subjects With A1c <7.0% | Subjects With A1c <6.5% | Subjects with a Decrease in A1c > Specific Value | Other A1c Outcome | Change in Primary and/or Secondary Outcome | Outcome in Methods Not Reported in Results | Outcome in Methods Not Fully Reported in Results | Outcome in Results Not Listed in Methods | Change in Analyses Between Methods and Results | Subgroup Results Not Described in Methods | SOR/SAR Present: Judgment #1 | ORBIT Class
No (%) | 0 (0) | 8 (33) | 12 (50) | 23 (96) | 22 (92) | 24 (100) | 24 (100) | 22 (92) | 21 (88) | 23 (96) | 19 (79) | 13 (54) | No SOR/SAR: 13
Yes (%) | 24 (100) | 16 (67) | 12 (50) | 1 (4) | 0 (0) | 0 (0) | 0 (0) | 2 (8) | 3 (13) | 1 (4) | 5 (21) | 11 (46) | A: 2;^a^ B:2; D: 3; E: 1; NA: 4

Abbreviations: NA, not applicable; ORBIT, Outcome Reporting Bias in Trials; SAR, selective analysis reporting; SOR, selective outcome reporting.

A, B, D, E are ORBIT classes (see Table 1).

a One of the 11 publications with SOR/SAR was assigned two ORBIT classes.

Data are number of trials (percentage of all trials where n=24 [A1c] and n=12 [fractures]), unless otherwise specified.

Table 8 Selective outcome reporting and selective analysis reporting for fractures (n=12) based on the publication only (judgment #1)

No/Yes | Types of Fractures Outcomes | | | | | | Discrepancies Between Publication Methods and Results
No/Yes | Total | Hip | Vertebral | Non Vertebral | Wrist | Other | Change in Primary and/or Secondary Outcome | Outcome in Methods Not Reported in Results | Outcome in Methods Not Fully Reported in Results | Outcome in Results Not Listed in Methods | Change in Analyses Between Methods and Results | Subgroup Results Not Described in Methods | SOR/SAR Present: Judgment #1 | ORBIT Class
No (%) | 1 (8) | 7 (58) | 6 (50) | 7 (58) | 8 (67) | 7 (58) | 12 (100) | 12 (100) | 12 (100) | 8 (67) | 12 (100) | 12 (100) | 8 (67) | No SOR/SAR: 8
Yes (%) | 11 (92) | 5 (42) | 6 (50) | 5 (42) | 4 (33) | 5 (42) | 0 (0) | 0 (0) | 0 (0) | 4 (33) | 0 (0) | 0 (0) | 4 (33) | ORBIT NA: 4

Abbreviations: NA, not applicable; ORBIT, Outcome Reporting Bias in Trials; SAR, selective analysis reporting; SOR, selective outcome reporting.

A, B, D, E are ORBIT classes (see Table 1).

a One of the 11 publications with SOR/SAR was assigned two ORBIT classes.

Data are number of trials (percentage of all trials where n=24 [A1c] and n=12 [fractures]), unless otherwise specified.

Table 9 Selective outcome reporting and selective analysis reporting for A1c and fracture outcomes based on the publication and on the registry (judgments #2 and #3)

Outcomes (Number of Studies) | No/Yes | Registry Without Consideration of Registry Results | | | | | | | With Registry Results
Outcomes (Number of Studies) | No/Yes | Change in Outcome Between Registry and Publication | Change in Status of Outcome^a^ Between the Registry and the Publication | Change in Followup Interval Between Registry and Publication | Outcome Not Reported in Publication but Listed in Registry | Outcome Reported in Publication but Not Reported in Registry | SOR/SAR Present: Judgment #2 (Registry Summary vs. Publication Results) | ORBIT Class (Judgment #2) | SOR/SAR Present: Judgment #3 (Registry Results vs. Publication Results) | ORBIT Class (Judgment #3)
A1c outcomes (n=24) | No (%) | 23 (96) | 24 (100) | 21 (88) | 24 (100) | 4 (17) | 4 (17) | No SOR/SAR: 4 | (No results: 8) | No SOR/SAR: 6 SOR/SAR NA: 8
A1c outcomes (n=24) | Yes (%) | 1 (4) | 0 (0) | 2 (8) | 0 (0) | 20 (83) | 20 (83) | ORBIT NA: 20 | 2/16 (13) | ORBIT NA: 2
Fracture outcomes (n=12) | No (%) | 12 (100) | 12 (100) | 9 (75) | 12 (100) | 5 (42) | 5 (42) | No SOR/SAR: 5 | (No results: 11) | SOR/SAR NA: 11
Fracture outcomes (n=12) | Yes (%) | 0 (0) | 0 (0) | 3 (25) | 0 (0) | 7 (58) | 7 (58) | ORBIT NA: 7 | 1/12 (8.3) | ORBIT NA: 1

Abbreviations: NA, not applicable; ORBIT, Outcome Reporting Bias in Trials; SAR, selective analysis reporting; SOR, selective outcome reporting.

a Change in designation of the index outcome as primary or secondary.

Data are number of trials (percentage of all trials where n=24 [A1c] and n=12 [fractures]), unless otherwise specified.

Table 10 Potential predictors of selective outcome reporting and selective analysis reporting for A1c and fracture outcomes

Outcomes | No/Yes | Author With Industry Affiliation | Study Drug Made by Study Sponsor^a^ | Assistance Authoring the Publication by Study Funder | Trial Registered in ClinicalTrials.gov | First Subject Recruited Before Trial Registered | Registry Reports Results | Change in the Index Outcome Between Original and Current Outcome Listed in the Registry
A1c outcomes (n=24 trials) | No (%) | 2 (8) | 0 (0) | 13 (54) | 1 (4) | 13 (54) | 8 (33) | 19 (79)
A1c outcomes (n=24 trials) | Yes (%) | 22 (92) | 23 (96) | 11 (46) | 23 (96) | 11 (46) | 16 (66) | 5 (21)
Fracture outcomes (n=12 trials) | No (%) | 8 (67) | 6 (50) | 10 (83) | 4 (33) | 11 (92) | 11 (92) | 11 (92)
Fracture outcomes (n=12 trials) | Yes (%) | 4 (33) | 6 (50) | 2 (17) | 8 (67) | 0 (0) | 1 (8) | 1 (8)

Abbreviations: SAR, selective analysis reporting; SOR, selective outcome reporting.

a The trial sponsor was not reported in one of the A1c trials.

Data are number of trials (percentage of all trials where n=24 [A1c] and n=12 [fractures]) unless otherwise specified.

### Hemoglobin A1c Outcomes

The cohort of trials reporting A1c (n=24) (Tables 7–9), reported this outcome in a variety of ways, both as a continuous and as a categorical variable (Table 7). In none of these trials did the designation of A1c as a primary or secondary outcome change within the publication and the outcomes listed in the methods section were always reported in the results. In two studies (8 percent) the outcome was not fully reported in the results (judgment #1: publication methods vs. results). In three studies (12.5 percent), however, A1c outcomes were reported in the results sections that were not mentioned in the methods section. In addition, in five studies (21 percent) subgroup data were presented on A1c that were not specified in the methods section of the publication, and in one other study the analytic approach changed between the methods and results section of the publication.

Thus in 46 percent (n=11) of the trials reporting A1c we judged SOR and/or SAR to be present based only on the publication (judgment #1: publication methods vs. results). In seven of those 11 studies (64 percent) we were able to assign an ORBIT class, but in the remaining four we could not. These latter situations were where outcomes were presented in the results that were not mentioned in the methods section.

When the A1c trial publications were examined along with information in the registry summary (but not the registry results) (judgment #2: registry summary vs. publication results), SOR or SAR were assessed as present in 20 studies (83 percent) (Table 9). In none of these trials could we designate an ORBIT class, as all entailed the addition of results to the trial publication that were not specified in the registry. Of the 16 trials with results in the registry, two were assessed as having SOR or SAR (judgment #3: registry results vs. publication results), and ORBIT classes did not apply as these two studies had results added to the publication that were not in the registry.

We report the frequency of prespecified potential predictors of SOR and SAR for A1c trials in Table 10. Ninety-two percent of studies had one or more authors who were an employee of the company sponsoring the study and making one or more of the intervention drugs. Almost half of studies (46 percent) received assistance from the study funder in authoring the publication. Also in 46 percent of studies, subject recruitment started before the trial was registered.

### Fracture Outcomes

The cohort of trials reporting the outcome of fractures (n=12) is summarized in Tables 8–9. These studies were much better reported than the A1c cohort, with only four studies (33 percent) reporting outcomes in the results section that were not mentioned in the methods section of the publication (judgment #1: publication methods vs. results). Likewise, there was much better agreement between trial registry outcome information and the reported results, although judgment #2 (registry summary vs. publication results) was still positive in 58 percent of studies. ORBIT class did not apply in any of these trials where SOR or SAR was judged to be present. Only one study of the eight registered in ClinicalTrials.gov had results reported in the registry and the results differed between the registry and the publication (judgment #3). Industry employment of the study authors (33 percent) was less common than for the A1c trials (92 percent).

### Mortality Outcomes

Among the cohort of trials that reported mortality outcomes with lipid agents (n=14), this outcome was always reported as an adverse events (Tables 6 and 11). Eight trials mentioned safety or adverse events in the methods section of the publication, but only one explicitly mentioned death as an outcome in the methods section (judgment #1: publication methods vs. results). None of these studies mentioned mortality as a primary or secondary outcome in the registry summary information (judgment #2: registry summary vs. publication results), and neither of the two studies reporting results in the registry mentioned mortality (judgment #3: registry results vs. publication results). As a result of the homogeneity of reporting across these studies and the fact that none of these studies prespecified mortality as a primary or secondary outcome of either benefit or harm, we did not explore this cohort of studies further.

Table 11 Reporting of mortality in studies of lipid-modifying agents (n=14 trials)

No/Yes | Trials With Adverse Events Mentioned in the Methods Section of the Publication | Trials With Mortality Mentioned in the Methods Section | Trials With Adverse Events Mentioned in the Registry Summary | Trials With Results in the Registry | Trials With Mortality Reported in the Registry
No (%) | 8 (57) | 13 (93) | 14 (100) | 12 (86) | 14 (100)
Yes (%) | 6 (43) | 1 (7) | 0 (0) | 2 (14) | 0 (0)

Data are number of trials (percentage of all trials where n=14).

### Timing of Study Registration

Trial registration occurred at various times during the course of included trials (Table 12). A minority of studies was registered before or in the same month that subject recruitment started (46 percent, 29 percent, and 0 percent in the CERs on oral hypoglycemic agents, lipid-modifying agents, and fracture prevention drugs, respectively). Studies that commenced before 2005 (the year ICMJE recommendations were implemented) reasonably could have been registered later in the course of the study. However, ClinicalTrials.gov was launched in 2000 so that registration could have occurred prior to commencement of subject recruitment for virtually all studies in our cohort which were all published in 2005 or later.

Table 12 Timing of study registration

Time of Study Registration | Oral Diabetes Medications for Adults With Type 2 Diabetes19 (n=24) | Comparative Effectiveness of Lipid-Modifying Agents24 (n=14) | Fractures in Men and Women With Low Bone Density or Osteoporosis26 (n=12)
Before recruitment started or in the same month that recruitment started | 11 (45.8%) | 4 (28.6%) | 0 (0.0%)
Before primary completion date, primary completion date for recruitment, or date recruitment completed (from publication) | 16 (66.7%) | 4 (28.6%) | 5 (41.7%)
Before study completion date | 18 (75.0%) | 7 (50.0%) | 7 (58.3%)
Before publication submitted | 19 (79.2%) | 10 (71.4%) | 8 (66.7%)
Before publication accepted | 21 (87.5%) | 10 (71.4%) | 9 (75.0%)
Before article first published online | 21 (87.5%) | 10 (71.4%) | 10 (83.3%)
Before publication printed | 21 (87.5%) | 11 (78.6%) | 10 (83.3%)
Before date of our review (Jan. 4, 2012) | 24 (100.0%) | 14 (100.0%) | 12 (100.0%)

Numbers in each row are cumulative.

### Changes in the Index Outcome in the Registry

We examined the proportion of trials with a change in the index outcome between the “original” outcome and the “current outcome” in the trial summary in the registry, and the timing of those changes (Table 13). Forty-two percent of trials in the CER on oral hypoglycemic agents had a change in some aspect of A1c measurement, whereas 16.7 percent of trials in the CER on fracture prevention had a change in the index outcome in the registry. The outcome of mortality was never mentioned in the trial summaries for the CER on lipid management, so there was no documentation of any changes.

Table 13 Timing of changes in the index outcome in the registry

Time of Change in Index Outcome | Oral Diabetes Medications for Adults With Type 2 Diabetes19 (n=24) | Fractures in Men and Women With Low Bone Density or Osteoporosis26 (n=12)
Before recruitment started or in the same month that recruitment started | 0 | 0
Before the primary completion date or the primary completion date for recruitment or before date that recruitment was completed (from trial publication) | 0 | 0
Before study completion date | 0 | 0
Before publication submitted to publishing journal | 1 | 0
Before publication accepted | 2 | 0
Before article first published online | 2 | 0
Before publication printed | 3 | 0
Before date of our review (Jan. 4, 2012) | 10 | 2
Total number of trials with a change in the index outcome (%) | 10/24 (41.7%) | 2/12 (16.7%)

Data are the cumulateive number of trials with a change in the index outcome for each time interval.

The timing of changes in the index outcome between the original and current outcome in the registry was variable (Table 13), and occurred late in the research and publication process. In seven of 24 RCTs examining A1c and in two of 12 RCTs reporting fractures, the change occurred after the date of publication of the trial.

We also examined whether our index outcome changed with respect to the posting of results in ClinicalTrials.gov, by reviewing the “History of Changes” in the registry. For the CER on oral hypoglycemic agents,19 of the 10 RCTs with changes in the specification of A1c, this outcome changed twice on the date the results were posted to the registry, and six times after the date the results were posted. (In two RCTs the results were not posted.) For the two trials where the outcome of fractures changed in the registry, one change occurred after the date the results were posted, and in the other trial no results were posted.

We illustrate the chronology of trial registration and changes in outcomes with three examples (Figures 4, 5, and 6). Dates above the horizontal line refer to dates from the publication; dates below the line are from the trial registry. Figure 4 provides an example of a reasonable study-registration chronology, wherein the study was registered at the time it was started and results were posted. Ideally, however, results would have been posted earlier, at the time of publication. Figures 5 and 6 illustrate suboptimal chronologies. In Figure 5, the trial was registered after the study was submitted for publication, and the results submitted 2 years later. In Figure 6 the study was also registered after publication and results were never reported.

Figure 4 Example of study and registry chronology (from Raz et al., 2008)41

Example of study and registry chronology. This figure provides an example of a study and registry chronology with the following events on a horizontal dateline: Study state: June 2006; Study registered: June 14, 2006; Primary complete date for recruitment: May 2007; Study completion date: August 2007; Publication accepted: December 14, 2007; Article first published online: January 11, 2008; Publication printed: February 2008; Results first received: September 14, 2009; Registry last updated: May 27, 2010

Figure 5 Example of study and registry chronology (from Scott et al., 2008)42

Example of study and registry chronology. This figure provides an example of a study and registry chronology with the following events on a horizontal dateline: Study state: June 2006; Primary complete date for recruitment: May 2007; Study completion date: March 2007; Publication submitted: September 26, 2007; Study registered: October 5, 2007; Publication accepted: November 14, 2007; Article first published online: January 14, 2008; Publication printed: October 2008; Results first received: March 17, 2010; Registry last updated: December 17, 2010

Figure 6 Example of study and registry chronology (from Rosenstock et al., 2006)43

Example of study and registry chronology. This figure provides an example of a study and registry chronology with the following events on a horizontal dateline: Study state: October 2003; Publication submitted: June 2, 2006; Publication accepted: August 11, 2006; Article first published online: October 4, 2006; Publication printed: November 2006; Study registered: July 9, 2007; Registry last updated: March 17, 2011

### Efforts Taken To Identify Selective Outcome Reporting and Selective Analysis Reporting

The time it took the two assessors to examine the trial registry for SOR and SAR is reported in Table 14. There was considerable variation across studies: examination of the summary information in the registry took as few as 3 minutes and as long as 25 (median 10, interquartile range [IQR] 6.5). Examination of trials with results in the registry took the two assessors 21 and 23 minutes on average for the studies examining A1c. We did not collect data for the report on lipid agents.

Table 14 Time to complete the review of ClinicalTrials.gov

Report | Mean Time Without Examination of Results (n, [range]; median; IQR) | | Mean Time with Examination of Results (n, ([range]; median; IQR)
Report | Reviewer 1 | Reviewer 2 | Reviewer 1 | Reviewer 2
Diabetes (n=24) | 13 (5 to 23); 13; 5.5 n=23 | 10 (3 to 25); 9; 6 n=18 | 23 (16 to 38); 21; 10 n=14 | 21 (9 to 34); 19; 8.5 n=12
Lipids (n=14) | NA | NA | NA | NA
Osteoporosis (n=12) | 10 (4 to 15); 9.5; 4 n=11 | 7 (3 to 15); 6; 3 n=12 | 17 (17 to 17); 17; 0 n=1^a^ | 19 (19 to 19); 19; 0 n=1 a

Abbreviations: NA, not applicable.

a The osteoporosis review only had one trial with results reported.

Time in minutes.

## Predictors of Selective Outcome Reporting

We explored the relationships between various prespecified characteristics of study authors, trial registration, and changes in the index outcome within the registry, and our assessment of SOR and SAR (judgments #1, #2, and #3 for the CERs on oral hypoglycemic agents and drugs for prevention of fractures). We analyzed both CERs separately and combined, and found no significant relationships (all p values >0.05), although our small sample size limited power to detect significant differences (Tables 15 and 16). There was not sufficient variation in the judgments of SOR and SAR for the CER on lipid-modifying agents and mortality to perform predictor analyses for that report.

Table 15 Oral hypoglycemic agents: Relationship between potential predictors and the judgment on selective outcome reporting and selective analysis reporting

Predictor | Total N | Judgment #1 | p value | Total N | Judgment #2 | p value | Total N | Judgment #3 | p value
One or more authors with industry affiliation^a^ | N (n=2) Y (n=22) | 0 11 | 0.482 | N (n=2) Y (n=22) | 2 18 | 1.000 | N (n=0) Y (n=16) | NA | NA
Intervention drug made by study sponsor^a^ | U (n=1) Y (n=23) | 1 10 | 0.458 | U (n=1) Y (n=23) | 1 19 | 1.000 | U (n=1) Y (n=15) | 0 2 | 1.000
Assistance authoring the publication by study sponsor^a^ | N (n=13) Y (n=11) | 6 5 | 1.000 | N (n=13) Y (n=11) | 10 10 | 0.596 | N (n=8) Y (n=8) | 2 0 | 0.467
Study registered in ClinicalTrials.gov^a^ | N (n=1) Y (n=23) | 0 11 | 1.000 | N (n=1) Y (n=23) | 1 19 | 1.000 | N (n=0) Y (n=16) | NA | NA
First subject recruitment occurred before (or during same month) study started^a^ | N (n=13) Y (n=11) | 5 6 | 0.682 | N (n=13) Y (n=11) | 11 9 | 1.000 | N (n=6) Y (n=10) | 1 1 | 1.000
Registry reported the results^a^ | N (n=9) Y (n=15) | 3 8 | 0.423 | N (n=9) Y (n=15) | 7 13 | 0.615 | N (n=1) Y (n=15) | 0 2 | 1.000
Change in A1c measure between original and current registry outcomes^a^ | N (n=19) Y (n=5) | 8 3 | 0.63 | N (n=19) Y (n=5) | 15 5 | 0.544 | N (n=12) Y (n=4) | 0 2 | 0.050
Number of authors with industry affiliation^b^ | OR (95% CI) | 0.839 0.505–1.322 | 0.5095 | OR (95% CI) | 1.028 0.561–1.976 | 1.000 | OR (95% CI) | 1.279 0.500–3.056 | 0.6167
Percent of authors with industry affiliation^b^ | OR (95% CI) | 0.979 0.948–1.011 | 0.203 | OR (95% CI) | 0.995 0.954–1.037 | 0.802 | OR (95% CI) | 0.990 0.929–1.056 | 0.768

Abbreviations: Y, Yes; N, No; U, Unsure; A1c, hemoglobin A1c; CI, confidence interval; NA, not applicable; OR, odds ratio.

a Fisher’s Exact test

b Logistic regression

Studies can have more than one judgment as “yes”, thus the rows can add up to more than the total number of trials.

Judgment #1: Publication methods compared with the publication results.

Judgment #2: Trial registry summary information compared with the publication results.

Judgment #3: Trial registry results compared with the publication results.

Table 16 Drugs for the prevention of fractures: Relationship between potential predictors and the judgment on selective outcome reporting and selective analysis reporting

Predictor | Total N | Judgment #1 | p value | Total N | Judgment #2 | p value
One or more authors with industry affiliation a | N (n=8) Y (n=4) | 2 2 | 0.547 | N (n=8) Y (n=4) | 5 2 | 1.000
Intervention drug made by study sponsor a | N (n=6) Y (n=6) | 1 3 | 0.545 | N (n=6) Y (n=6) | 4 3 | 1.000
Assistance authoring the publication by study sponsor a | N (n=10) Y (n=2) | 3 1 | 1.000 | N (n=10) Y (n=2) | 6 1 | 1.000
Study registered in ClinicalTrials.gov a | N (n=4) Y (n=8) | 0 4 | 0.208 | N (n=4) Y (n=8) | 2 5 | 1.000
First subject recruitment occurred before (or during same month) study started a | N (n=11) Y (n=1) | 4 0 | 1.000 | N (n=11) Y (n=1) | 6 1 | 1.000
Registry reported the results a | N (n=11) Y (n=1) | 3 1 | 0.333 | N (n=11) Y (n=1) | 6 1 | 1.000
Number authors with industry affiliation b | OR (95% CI) | 1.337 0.752–2.722 | 0.3879 | OR (95% CI) | 0.960 0.560–1.677 | 0.975
Percent authors with industry affiliation b | OR (95% CI) | 1.075 0.980–1.178 | 0.126 | OR (95% CI) | 0.040 0.929–1.086 | 0.909

Abbreviations: Y, Yes; N, No; U, Unsure; CI, confidence interval; OR, odds ratio.

a Fisher’s Exact.

b Logistic regression.

Judgment #1: Publication methods compared with the publication results.

Judgment #2: Trial registry summary information compared with the publication results.

Judgment #3: Trial registry results compared with the publication results.

## Reliability and Validity of ORBIT

We were not able to examine the inter-rater reliability of the ORBIT classification system. for two reasons. First, because of the design of our study, very few trials were assessed as having an ORBIT class, and, by design, ORBIT classes G and H were not identified. We could potentially have examined the reliability of ORBIT classes A through D, but did not have sufficient number of studies with those classes to perform that assessment.

Second, the two assessors found that more trials than the initially proposed pilot of four trials were required to understand the types of SOR and SAR. Each additional trial appeared somewhat different in its presentation of SOR and SAR, and there were a multitude of nuances. The two assessors therefore altered their categorization of SOR and SAR (judgments #1, #2, and #3) during their consensus process. We did not feel that an assessment of inter-rater reliability would be particularly useful with such a process.

Our proposed assessment of the validity of ORBIT proved infeasible, in large part due to our study design. Because we had restricted our cohort of trials to those that reported the index outcome, that outcome (defined broadly, e.g., A1c) had to be reported in our cohort of RCTs and ORBIT classes G and H were thus not identified. Only these two ORBIT classes are applicable to a validation study with comparison of the outcomes that should have been reported (based on clinical judgment) to information contained in sources outside of the study publication (i.e., to registry information in our study).