# References

1 Sterne J, Egger M, Moher D. Addressing reporting biases, Cochrane Handbook for Systematic Reviews of Interventions. Chichester. John Wiley & Sons Ltd. 2008:297-333.
2 Hutton JL, Williamson PR. Bias in meta-analysis due to outcome variable selection within studies. Applied Statistics 2000. 2002;49(3):359-70.
3 Kirkham JJ, Dwan KM, Altman DG, et al. The impact of outcome reporting bias in randomised controlled trials on a cohort of systematic reviews. BMJ. 2010;340:c365. [pmid: 20156912].
4 Higgins J, Altman D. Assessing risk of bias in included studies, Cochrane Handbook for Systematic Reviews of Interventions. Chichester. John Wiley & Sons Ltd. 2008:187-242.
5 Dickersin K, Chalmers I. Recognising, investigating and dealing with incomplete and biased reporting of clinical research: from Francis Bacon to the World Health Organisation. James Lind Library. 2010.
6 Dwan K, Altman DG, Arnaiz JA, et al. Systematic Review of the Empirical Evidence of Study Publication Bias and Outcome Reporting Bias. PLoS ONE. 2008;3(8):e3081. [pmid: 18769481].
7 Song F, Parekh S, Hooper L, et al. Dissemination and publication of research findings: an updated review of related biases. Health Technol Assess. 2010;14(8):1-220.
8 Copas J, Jackson D. A Bound for Publication Bias Based on the Fraction of Unpublished Studies. Biometrics. 2004;60(1):146-53. [pmid: 15032784].
9 Hart B, Lundh A, Bero L, et al. Effect of reporting bias on meta-analyses of drug trials: reanalysis of meta-analyses. BMJ. 2012;344:d7202. [pmid: 22214754].
10 Dickersin K. The existence of publication bias and risk factors for its occurrence. JAMA. Mar. 9. 1990;263(10):1385-9. [pmid: 2406472].
11 Dickersin K, Chan S, Chalmers TC, et al. Publication bias and clinical trials. Controlled Clinical Trials. Dec. 1987;8(4):343-53. [pmid: 3442991].
12 Hopewell S, Loudon K, Clarke M. Publication bias in clinical trials due to statistical significance or direction of trial results. Cochrane Database Syst Rev. 2009;1:MR000006. [pmid: 19160345].
13 Stern JM, Simes RJ. Publication bias: evidence of delayed publication in a cohort study of clinical research projects. BMJ. Sep. 13. 1997;315(7109):640-5. [pmid: 9310565].
14 Dickersin K, Olson CM, Rennie D, et al. Association between time interval to publication and statistical significance. JAMA. Jun. 5. 2002;287(21):2829-31. [pmid: 12038925].
15 Gotzsche PC. Reference bias in reports of drug trials. British Medical Journal Clinical Research Ed. Sep. 12. 1987;295(6599):654-6. [pmid: 3117277].
16 Food and Drug Administration Modernization Act of 1997. 1997. Pub L No. 105-115.
17 United States Code. US Public Law 110-85: Food and Drug Administration Amendments Act of 2007. 2008. http://frwebgate.access.gpo.gov/cgi-bin/getdoc.cgi?dbname=110_cong_public_laws&docid=f:publ085.110. Accessed on May 7, 2012.
18 World Health Organization. International Clinical Trials Registry Platform (ICTRP). 2011. www.who.int/ictrp/en/. Accessed on August 9, 2011.
19 Bennett W, Wilson L, Bolen S, et al. Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update. Comparative Effectiveness Review No. 27. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No 290-02-0018) AHRQ Publication No 11-EHC038-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
20 Phung OJ, Coleman CI, Baker EL, et al. Effectiveness of Recombinant Human Growth Hormone (rhGH) in the Treatment of Patients With Cystic Fibrosis. Comparative Effectiveness Review No. 23. (Prepared by the University of Connecticut/Hartford Evidence-based Practice Center under Contract No. 290-2007-10067-I). AHRQ Publication No. 11-EHC003. Rockville, MD. Agency for Healthcare Research and Quality. October. 2010. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
21 Yank V, Tuohy CV, Logan AC, et al. Comparative Effectiveness of Recombinant Factor VIIa for Off-Label Indications vs Usual Care. Comparative Effectiveness Review No. 21. (Prepared by Stanford-UCSF Evidence-based Practice Center under Contract No #290-02-0017). Rockville, MD. Agency for Healthcare Research and Quality. May. 2010. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
22 Coleman CI, Baker WL, Kluger J, et al. Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease. (Prepared by the University of Connecticut/Hartford Hospital Evidence-based Practice Center under Contract No. 290-2007-10067-I). Rockville, MD. Agency for Healthcare Research and Quality. October. 2009. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
23 Nelson HD, Fu R, Humphrey L, et al. Comparative Effectiveness of Medications To Reduce Risk of Primary Breast Cancer in Women. Comparative Effectiveness Review No. 17. (Prepared by Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-1). Rockville, MD. Agency for Healthcare Research and Quality. September. 2009. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
24 Sharma M, Ansari M, Soares-Weiser K, et al. Comparative Effectiveness of Lipid-Modifying Agents Comparative. Effectiveness Review No. 16. (Prepared by the University of Ottawa Evidence-based Practice Center under contract No. 290-02-0021). Rockville, MD. Agency for Healthcare Research and Quality. September. 2009. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
25 Qayyum R, Wilson LM, Bolen S, et al. Comparative Effectiveness, Safety, and Indications of Insulin Analogues in Premixed Formulations for Adults with Type 2 Diabetes. Comparative Effectiveness Review No. 14. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No 290-02-0018). Rockville, MD. Agency for Healthcare Research and Quality. September. 2008. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
26 MacLean C, Alexander A, Carter J, et al. Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis. Comparative Effectiveness Review No. 12. (Prepared by Southern California/RAND Evidence-based Practice Center under Contract No 290-02-0003). Rockville, MD. Agency for Healthcare Research and Quality. December. 2007. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
27 Donahue KE, Gartlehner G, Jonas DE, et al. Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults. Comparative Effectiveness Review No. 11. (Prepared by RTI-University of North Carolina Evidence-based Practice Center under Contract No 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. November. 2007. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
28 Matchar DB, McCrory DC, Orlando LA, et al. Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension. Comparative Effectiveness Review No. 10. (Prepared by Duke Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. November. 2007. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
29 Gartlehner G, Hansen RA, Thieda P, et al. Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression. Comparative Effectiveness Review No. 7. (Prepared by RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
30 Shekelle P, Maglione M, Bagley S, et al. Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics. Comparative Effectiveness Review No. 6. (Prepared by the Southern California/RAND Evidence-based Practice Center under Contract No. 290-02-0003). Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
31 Chou R, Helfand M, Peterson K, et al. Comparative Effectiveness and Safety of Analgesics for Osteoarthritis. Comparative Effectiveness Review No. 4. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024). Rockville, MD. Agency for Healthcare Research and Quality. September. 2006. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
32 Seidenfeld J, Piper M, Bohlius J, et al. Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment. Comparative Effectiveness Review No. 3. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-02- 0026). Rockville, MD. Agency for Healthcare Research and Quality. May. 2006. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
33 Ip S, Bonis P, Tatsioni A, et al. Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease. Comparative Effectiveness Review No. 1. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. December. 2005. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
34 Zarin DA, Tse T, Williams RJ, et al. The ClinicalTrials.gov results database--update and key issues. New England Journal of Medicine. Mar. 3. 2011;364(9):852-60. [pmid: 21366476].
35 FDA Failed to Enforce Law Requiring Drugmakers to Disclose Test Data. WashPost. 2004.
36 Zarin DA, Ide NC, Tse T, et al. Issues in the registration of clinical trials. JAMA. May. 16. 2007;297(19):2112-20. [pmid: 17507347].
37 Als-Nielsen B, Chen W, Gluud C, et al. Association of funding and conclusions in randomized drug trials: a reflection of treatment effect or adverse events?. JAMA. Aug. 20. 2003;290(7):921-8. [pmid: 12928469].
38 Bekelman JE, Li Y, Gross CP. Scope and Impact of Financial Conflicts of Interest in Biomedical Research. JAMA: The Journal of the American Medical Association. January. 22. 2003. 2003;289(4):454-65. [pmid: 12533125].
39 Lexchin J, Bero LA, Djulbegovic B, et al. Pharmaceutical industry sponsorship and research outcome and quality: systematic review. BMJ. May. 31. 2003;326(7400):1167-70. [pmid: 12775614].
40 Sismondo S, Sismondo S. How pharmaceutical industry funding affects trial outcomes: causal structures and responses. Social Science & Medicine. May. 2008;66(9):1909-14. [pmid: 18299169].
41 Raz I, Chen Y, Wu M, et al. Efficacy and safety of sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes. Current Medical Research & Opinion. Feb. 2008;24(2):537-50. [pmid: 18194595].
42 Scott R, Loeys T, Davies MJ, et al. Efficacy and safety of sitagliptin when added to ongoing metformin therapy in patients with type 2 diabetes. Diabetes, Obesity & Metabolism. Sep. 2008;10(10):959-69. [pmid: 18201203].
43 Rosenstock J, Rood J, Cobitz A, et al. Initial treatment with rosiglitazone/metformin fixed-dose combination therapy compared with monotherapy with either rosiglitazone or metformin in patients with uncontrolled type 2 diabetes. Diabetes, Obesity & Metabolism. Nov. 2006;8(6):650-60. [pmid: 17026489].
44 Easterbrook PJ, Berlin JA, Gopalan R, et al. Publication bias in clinical research. Lancet. Apr. 13. 1991;337(8746):867-72. [pmid: 1672966].
45 Bekkering GE, Harris RJ, Thomas S, et al. How much of the data published in observational studies of the association between diet and prostate or bladder cancer is usable for meta-analysis?. American Journal of Epidemiology. May. 1. 2008;167(9):1017-26. [pmid: 18403406].
46 Williamson P, Clarke M. The COMET (Core Outcome Measures in Effectiveness Trials). Initiative: its role in improving Cochrane Reviews. [editorial]. The Cochrane Library. Accessed May 7, 2012. 2012. www.thecochranelibrary.com/details/editorial/1797057/The-COMET-Core-Outcome-Measures-in-Effectiveness-Trials-Initiative-its-role-in-i.html. Accessed on May 7, 2012.
47 Golder S, Loke YK. Is there evidence for biased reporting of published adverse effects data in pharmaceutical industry-funded studies?. British Journal of Clinical Pharmacology. Dec. 2008;66(6):767-73. [pmid: 18754841].
48 About the ClinicalTrials.gov. Results Database. 2011. http://clinicaltrials.gov/ct2/info/results. Accessed on January 5, 2012.
49 Chan AW, Chan AW. Out of sight but not out of mind: how to search for unpublished clinical trial evidence. BMJ. 2012;344:d8013. [pmid: 22214892].
50 Mathieu S, Boutron I, Moher D, et al. Comparison of registered and published primary outcomes in randomized controlled trials. [Erratum appears in JAMA. 2009 Oct 14;302(14):1532]. JAMA. Sep. 2. 2009;302(9):977-84. [pmid: 19724045].